# D APPENDIX HEALTHCARE COST STUDIES

Source | Pathogen | Infection Site | Resistance | Parameter Reported | Year | Cost (in Year Reported $) | Cost (in 2020 $) | Lower Bound | Upper Bound
(CDC, 2019) | Enterobacterales | Any Infection | Carbapenem Resistance | Excess Healthcare Cost | 2017 | $9,924 | $10,771 | NA | NA
(Branch-Elliman, et al., 2013) | Staphylococcus aureus | ABSSSI | Multi-Drug Resistance | Excess Healthcare Cost | 2012 | $507 | $627 | -$1,011 | $2,277
(Kadri, et al., 2019) | GNI | Any Infection | Proxy of resistance (Colistin for 4 days equates to XDR) | Excess Healthcare Cost | 2014 | $35,856 | $42,207 | NA | NA
(MacVane, et al., 2014) | ESBL+E. coli | UTI | Not determined | Excess Healthcare Cost | 2012 | $3,658 | $4,523 | NA | NA
(MacVane, et al., 2014) | ESBL+Klebsiella spp. | UTI | Not determined | Excess Healthcare Cost | 2012 | $3,658 | $4,523 | NA | NA
(Neidell, et al., 2012) | K. pneumoniae | Any Infection | Carbapenem Resistance | Excess Healthcare Cost | 2008 | $13,200 | $18,602 | -$8,315 | $45,378
(Neidell, et al., 2012) | P. aeruginosa | Any Infection | Fluoroquinolone Resistance | Excess Healthcare Cost | 2008 | $31,400 | $44,251 | $14,234 | $74,409
(Neidell, et al., 2012) | Not determined | BSI | Resistant | Excess Healthcare Cost | 2008 | $27,100 | $38,191 | $8,456 | $67,927
(Neidell, et al., 2012) | Not determined | UTI | Resistant | Excess Healthcare Cost | 2008 | $4,300 | $6,060 | -$28,608 | $40,587
(Neidell, et al., 2012) | Not determined | Pneumon ia | Resistant | Excess Healthcare Cost | 2008 | $14,300 | $20,153 | $7,751 | $32,695
(Nelson, et al., 2021) | Invasive Enterobacterales | Any Infection | Carbapenem Resistance | Healthcare Cost | 2017 | $8,354 | $9,067 | -$1,293 | $19,427
(Nelson, et al., 2021) | Non-invasive Enterobacterales | Any Infection | Carbapenem Resistance | Healthcare Cost | 2017 | $5,154 | $5,594 | $985 | $10,202
(Nelson, et al., 2021) | Invasive Enterobacteriacea | Any Infection | Extended-Spectrum Cephalosporin Resistance | Healthcare Cost | 2017 | $33,637 | $36,508 | $21,787 | $51,228
(Nelson, et al., 2021) | Non-invasive Enterobacteriacea | Any Infection | Extended-Spectrum Cephalosporin Resistance | Healthcare Cost | 2017 | $16,240 | $17,626 | $12,282 | $22,969
(Nelson, et al., 2021) | Invasive Acinetobacter | Any Infection | Carbapenem Resistance | Healthcare Cost | 2017 | $74,306 | $80,648 | $22,116 | $139,180
(Nelson, et al., 2021) | Non-invasive Acinetobacter | Any Infection | Carbapenem Resistance | Healthcare Cost | 2017 | $30,590 | $33,201 | $13,875 | $52,527
(Nelson, et al., 2021) | Invasive Pseudomonas | Any Infection | Multi-Drug Resistance | Healthcare Cost | 2017 | $66,934 | $72,647 | $35,755 | $109,539
(Nelson, et al., 2021) | Non-invasive Pseudomonas | Any Infection | Multi-Drug Resistance | Healthcare Cost | 2017 | $50,810 | $55,147 | $44,567 | $65,727
(Nelson, et al., 2021) | Invasive Enterobacteriaceae | Any Infection | Multi-Drug Resistance | Healthcare Cost | 2017 | $54,614 | $59,275 | $29,296 | $89,255
(Nelson, et al., 2021) | Non-invasive Enterobacteriaceae | Any Infection | Multi-Drug Resistance | Healthcare Cost | 2017 | $16,606 | $18,023 | $9,425 | $26,623
(Thaden, et al., 2017) | E. coli | BSI | Resistant & Susceptible | Healthcare Cost | 2015 | $14,776 | $16,960 | $4,937 | $15,435
(Thaden, et al., 2017) | E. coli | BSI | Multi-Drug Resistance | Healthcare Cost | 2015 | $18,917 | $21,714 | $6,789 | $22,553
(Thaden, et al., 2017) | K. pneumoniae | BSI | Resistant & Susceptible | Healthcare Cost | 2015 | $28,877 | $33,146 | $6,835 | $33,806
(Thaden, et al., 2017) | K. pneumoniae | BSI | Multi-Drug Resistance | Healthcare Cost | 2015 | $115,868 | $132,998 | $14,314 | $176,631
(Thaden, et al., 2017) | Enterobacter spp. | BSI | Resistant & Susceptible | Healthcare Cost | 2015 | $42,717 | $49,032 | $7,682 | $50,070
(Thaden, et al., 2017) | Enterobacter spp. | BSI | Multi-Drug Resistance | Healthcare Cost | 2015 | $108,163 | $124,154 | $22,128 | $190,846
(Thorpe, et al., 2018) | Not determined | Any Infection | Resistant | Excess Healthcare Cost | 2014 | $1,383 | $1,628 | $1,234 | $2,021
(Zimlichman, et al., 2013) | Not determined | SSI | Resistant & Susceptible | Healthcare Cost | 2012 | $20,785 | $25,698 | $23,369 | $28,024
(Zimlichman, et al., 2013) | Staphylococcus aureus | SSI | Multi-Drug Resistance | Healthcare Cost | 2012 | $42,300 | $52,298 | $4,952 | $102,209
(Zimlichman, et al., 2013) | Not determined | BSI | Resistant & Susceptible | Healthcare Cost | 2012 | $45,814 | $56,642 | $38,227 | $80,666
(Zimlichman, et al., 2013) | Staphylococcus aureus | BSI | Multi-Drug Resistance | Healthcare Cost | 2012 | $58,614 | $72,467 | $20,721 | $216,058
(Zimlichman, et al., 2013) | Not determined | UTI | Resistant & Susceptible | Healthcare Cost | 2012 | $896 | $1,108 | $746 | $1,470
(Zimlichman, et al., 2013) | Not determined | Pneumon ia | Resistant & Susceptible | Healthcare Cost | 2012 | $40,144 | $49,632 | $44,862 | $54,671