# C APPENDIX INCLUDED STUDIES BY PATHOGEN AND DRUG

Table C-17 General Study Information, Carbapenem-Resistant A. baumannii

Reference | Study Design | Enrollment Period | Country | Resistance Reference | Setting | Infection Site | Overall Score
(Aydemir, et al., 2012) | Retrospective case-control study | 1/2005-12/2006 | Turkey | CLSI | Single (350-bed referral and tertiary care hospital) | Not determined | 5.5
(Balkhair, et al., 2019) | Retrospective study | 1/2007-12/2016 | Oman | CLSI | Single (600 bed teaching and referral hospital) | BSI | 6.0
(Baran, et al., 2008) | Prospective case-control study | 1/2004-12/2004 | Turkey | Not reported | Single (1100-bed referral and tertiary-care hospital) | Any infection | 5.0
(Cai, et al., 2017) | Cohort study | 1/1/2009-12/31/2013 | U.S. | CLIA | Premier Healthcare Database | BSI; respiratory; urinary; other; any infection | 24.0
(Chang, et al., 2011) | Retrospective observational study | 1/2005-12/2007 | Taiwan | Not reported | Single (2500-bed primary care facility and tertiary referral center) | VAP | 5.5
(Choi, et al., 2019) | Retrospective cohort study | 1/2006-12/2016 | Korea | CLSI | Single (850-bed tertiary care-affiliated hospital) | Any infection; lungs; central venous catheter; biliary tract; central nervous system; abdomen; UTI; skin/soft tissue | 7.2
(de Gouvêa, et al., 2012) | Retrospective study | 1/2002-1/2009 | Brazil | CLSI | Single | Any infection | 4.0
(Deris, et al., 2011) | Cross sectional descriptive and case-control study | Not Reported | Malaysia | CLSI | Single (teaching hospital) | BSI | 4.0
(Esterly, et al., 2011) | Retrospective cohort study | 1/2005-12/2008 | U.S. | CLSI | Single | BSI | 18.0
(Freire, et al., 2015) | Prospective cohort study | 10/2009-10/2011 | Brazil | CLSI | Single | Any infection; surgical wound/organ space; respiratory tract; BSI; skin or soft tissue; UTI | 6.2
(Henig, et al., 2015) | Matched case-control study | 1/2007-8/2012 | Israel | Not reported | Database | Any infection | 6.3
(Huang, et al., 2012) | Retrospective cohort study | 6/2002-12/2007 | Taiwan | CLSI | Single (veterans general hospital) | Any infection | 7.0
(Jamulitrat, et al., 2009) | Retrospective cohort study | 7/2004-9/2007 | Thailand | Not reported | Single (three ICUs at 850-bed medical school, training, and referral center) | BSI | 7.0
(Kim, et al., 2012) | Retrospective case-control study | 1/2008-12/2009 | Korea | CLSI | Single ICU (2000-bed university, tertiary, referral hospital with 117-bed ICU) | BSI | 7.0
(Kim, et al., 2018) | Retrospective cohort study | 1/2008-4/2015 | Korea | CLSI | Single (1200-bed tertiary care university hospital) | BSI | 7.0
(Lemos, et al., 2014) | Prospective cohort study | 4/2006-4/2010 | Columbia | CLSI | Multi (3 ICUs consisting of 42 beds, at 3 tertiary-care hospitals consisting of 887 beds) | Any infection | 7.5
(Liu, et al., 2016) | Retrospective study | 1/2009-12/2012 | Taiwan | CLSI | Single (2200-bed tertiary teaching hospital) | Any infection | 6.0
(Liu, et al., 2020) | Prospective study | 1/2007-12/2016 | China | CLSI | Multi (13 tertiary-care hospitals each with over 1500 beds) | BSI | 7.0
(Munoz-Price, et al., 2010) | Retrospective medical chart review | 1/2005-4/2006 | U.S. | Not Reported | Multi (4 tertiary care hospitals and a long-term acute care hospital) | BSI | 12.0
(Nutman, et al., 2014) | Case-control study | 7/2008-6/2011 | Israel | CLSI | Single (1300-bed tertiary care teaching hospital) | Any infection | 5.0
(Papadimitriou-Olivgeris, et al., 2017) | Retrospective case-control study | 1/2010-12/2005 | Greece | EUCAST | Single (13-bed ICU at university general hospital) | BSI | 12.0
(Prates, et al., 2011) | Retrospective cohort study | 3/2006-12/2008 | Brazil | CLSI | Single (ICU at 300-bed tertiary-care hospital) | Any infection | 7.0
(Rossi, et al., 2019) | Retrospective study | 1/2013-12/2017 | Brazil | Not reported | Single (530-bed teaching medical center) | BSI, respiratory tract, UTI, & SSI | 7.0
(Routsi, et al., 2010) | Prospective observational study | 9/2004-1/2006 | Greece | CLSI | Single (25-bed university ICU in a 1000-bed, tertiary-care, teaching hospital for adults) | Any infection | 6.0
(Sheng, et al., 2010) | Retrospective study | 5/2004-12/2006 | Taiwan | CLSI | Multi (7 medical centers that provide both primary and tertiary care, and 3 community hospitals that provide primary care) | Any infection | 4.0
(Song, et al., 2011) | Retrospective study | 1/2005-12/2010 | Korea | CLSI | Single (1000-bed tertiary care university hospital) | Any infection | 4.0
(Yang, et al., 2013) | Retrospective study | 1/2000-12/2008 | Taiwan | CLSI | Single (2900-bed tertiary-care teaching hospital) | Any infection | 5.0
(Zheng, et al., 2013) | Retrospective cohort study | 1/2006-12/2011 | China | CLSI | Single (1,500-bed referral and tertiary care hospital) | Any infection | 6.0

Table C-18 Study Mortality Information, Carbapenem-Resistant A. baumannii

Reference | Mortality for Resistant Strain | Mortality for Susceptible Strain | Excess Mortality | p-value | Standard Error in Resistant-Strain Mortality
(Aydemir, et al., 2012) | 62% | 53% | 9% | 0.341 | 5%
(Balkhair, et al., 2019) | 55% | 8% | 40% | 0.000 | 5%
(Cai, et al., 2017) | 38% | 14% | 25% | Not reported | 3%
(Cai, et al., 2017) ^[a]^ | 26% | 20% | 6% | Not reported | 1%
(Cai, et al., 2017) | 10% | 6% | 3% | Not reported | 2%
(Cai, et al., 2017) | 16% | 8% | 8% | Not reported | 1%
(Cai, et al., 2017) | 21% | 12% | 9% | Not reported | 1%
(Chang, et al., 2011) | 61% | 46% | 15% | 0.039 | 5%
(Choi, et al., 2019) | 52% | Not studied | Not studied | Not studied | 5%
(Choi, et al., 2019) | 57% | Not studied | Not studied | Not studied | Unknown
(Choi, et al., 2019) | 68% | Not studied | Not studied | <.001 | 6%
(Choi, et al., 2019) | 13% | Not studied | Not studied | 0.001 | 9%
(Choi, et al., 2019) | 60% | Not studied | Not studied | 0.52 | 13%
(Choi, et al., 2019) | 0% | Not studied | Not studied | 0.01 | Unknown
(Choi, et al., 2019) | 50% | Not studied | Not studied | 1 | 25%
(Choi, et al., 2019) | 50% | Not studied | Not studied | 1 | 25%
(Choi, et al., 2019) | 25% | Not studied | Not studied | 0.35 | 22%
(Choi, et al., 2019) | 0% | Not studied | Not studied | 0.48 | Unknown
(de Gouvêa, et al., 2012) | 50% | Not studied | Not studied | 0.15 | 12%
(Deris, et al., 2011) | 40% | 22% | 18% | 0.201 | 13%
(Esterly, et al., 2011) | 57% | 24% | 33% | <.001 | 8%
(Freire, et al., 2015) | 71% | Not studied | Not studied | Not studied | 6%
(Freire, et al., 2015) | 50% | Not studied | Not studied | Not studied | 11%
(Freire, et al., 2015) | 58% | Not studied | Not studied | Not studied | 11%
(Freire, et al., 2015) | 67% | Not studied | Not studied | Not studied | 12%
(Freire, et al., 2015) | 100% | Not studied | Not studied | Not studied | Unknown
(Freire, et al., 2015) | 0% | Not studied | Not studied | Not studied | Unknown
(Henig, et al., 2015) | 73% | 55% | 18% | Not reported | Unknown
(Huang, et al., 2012) | 35% | 20% | 15% | Not reported | 6%
(Jamulitrat, et al., 2009) | 52% | 20% | 32% | <.001 | 6%
(Kim, et al., 2012) | 80% | Not studied | Not studied | Not studied | 4%
(Kim, et al., 2018) | 50% | Not studied | Not studied | Not studied | 13%
(Lemos, et al., 2014) | 40% | 21% | 19% | 0.018 | 5%
(Liu, et al., 2016) | 58% | Not studied | Not studied | Not studied | 4%
(Liu, et al., 2020) | 30% | 5% | 25% | <.001 | 3%
(Munoz-Price, et al., 2010) | 41% | Not studied | Not studied | Not studied | 5%
(Nutman, et al., 2014) | 45% | Not studied | Not studied | Not studied | Unknown
(Papadimitriou-Olivgeris, et al., 2017) | 40% | Not studied | Not studied | Not studied | 4%
(Prates, et al., 2011) | 47% | Not studied | Not studied | Not studied | 6%
(Rossi, et al., 2019) | 39% | Not studied | Not studied | <.0001 | 2%
(Routsi, et al., 2010) | 43% | 47% | -4% | 0.74 | 9%
(Sheng, et al., 2010) | 33% | 18% | 15% | 0.01 | 5%
(Song, et al., 2011) | 54% | Not studied | Not studied | Not studied | 9%
(Yang, et al., 2013) | 48% | Not studied | Not studied | 0.001 | 6%
(Zheng, et al., 2013) | 30% | 46% | -16% | 0.02 | Unknown

[a] For studies with multiple mortality estimates (e.g., associated with different pathogen-drug combinations, or with different infection sites), all extracted estimates are listed in these tables.

Table C-19 Study Length of Stay Information, Carbapenem-Resistant A. baumannii

Reference | Resistant Strain Sample Size | Susceptible Strain Sample Size | Resistant Strain LOS (Days) | Susceptible Strain LOS (Days) | Excess LOS (Days) | p-value
(Aydemir, et al., 2012) | 110 | 55 | 40.5 | 32.2 | 8.3 | Not Reported
(Baran, et al., 2008) | 66 | 57 | 43 | 23 | 20 | 0.006
(Chang, et al., 2011) | 93 | 87 | 23.1 | 26.7 | -3.6 | 0.331
(Deris, et al., 2011) | 15 | 41 | 32.3 | 32.8 | -0.5 | 0.939
(Esterly, et al., 2011) | 37 | 42 | 28 | 6 | 22 | Not Reported
(Henig, et al., 2015) | 1190 | 1190 | 18 | 17 | 1 | <.0001
(Henig, et al., 2015) | 241 | 241 | 16 | 15 | 1 | Not Reported
(Jamulitrat, et al., 2009) | 67 | 131 | 37 | 27 | 10 | 0.07
(Kim, et al., 2018) | 14 | Not Studied | 17.7 | Not Studied | Not Studied | 0.05
(Lemos, et al., 2014) | 104 | 61 | 19.3 | 16.2 | 3.1 | 0.58
(Munoz-Price, et al., 2010) | 86 | Not Studied | 36 | Not Studied | Not Studied | Not Studied
(Rossi, et al., 2019) | 489 | Not Studied | 58 | Not Studied | Not Studied | <.0001
(Routsi, et al., 2010) | 30 | 66 | 8 | 15.5 | -7.5 | 0.834
(Sheng, et al., 2010) | 91 | 97 | 37 | 23 | 14 | 0.009

Table C-20 General Study Information, MDR A. baumannii

Reference | Study Design | Enrollment Period | Country | Resistance Reference | Setting | Infection Site | Overall Score
(Almomani, et al., 2015) | Retrospective case series study | 1/2007-6/2013 | Jordan | CLSI | Single (critical care units at 497-bed tertiary referral teaching hospital) | Ventilator-associated pneumonia | 6.0
(Anunnatsiri & Tonsawan, 2011) | Retrospective study | 2005-2007 | Thailand | CLSI | Single (1,000-bed tertiary-care university hospital) | Intra-abdominal, UTI, sinus & skin/soft tissue | 4.5
(Blanco, et al., 2018) | Retrospective cohort analysis | 5/2005-11/2009 | U.S. | CLSI | Single (medical intensive care unit and surgical intensive care unit at 816-bed university hospital) | Not Reported | 18.0
(Brahmi, et al., 2007) | Prospective study | 1/2004-12/2005 | Tunisia | CLSI | Single (16-bed ICU) | Not Reported | 3.0
(Brotfain, et al., 2017) | Retrospective study | 1/2005-6/2011 | Israel | Not reported | Single (1000-bed tertiary-care university teaching hospital) | Respiratory tract infections from ventilator associated pneumonia | 6.0
(Cornejo-Juárez, et al., 2020) | Retrospective study | 1/2011-12/2015 | Mexico | CLSI | Single (six bed ICU at 135-bed tertiary-care cancer hospital) | Any infection | 6.5
(Daniels, et al., 2008) | Retrospective propensity-matched cohort study | 7/2003-6/2006 | U.S. | CLSI | Single (large university affiliated tertiary care facility) | Ventilator-associated pneumonia, BSI, UTI | 19.5
(Fukuta, et al., 2013) | Case-control study | 1/2008-12/2011 | U.S. | CLSI | Single (520-bed major tertiary care facility with 53 beds for oncology and hematology patients) | Respiratory | 15.0
(Guo, et al., 2016) | Retrospective study | 6/2012-6-2015 | China | CLSI | Single | Any infection | 6.0
(Kuo, et al., 2007) | Retrospective study | 1/2003-2/2005 | Taiwan | CLSI | Single (2200-bed tertiary care center | Any infection | 4.0
(Lee, et al., 2007) | Retrospective, matched-cohort study | 4/1996-8/2001 | Taiwan | Not reported | Single (900 beds including 67 ICU- tertiary university hospital) | BSI | 5.5
(Liu, et al., 2015) | Retrospective study | 1/2009-12/2013 | China | CLSI | Single (4,000 bed tertiary hospital) | Any infection | 6.0
(Pierri, et al., 2016) | Retrospective cohort | 9/2009-12/2011 | Italy | CLSI | Single (893 bed tertiary-7 ICUs and 1 Emergency Medicine) | Any infection | 12.0
(Prata-Rocha, et al., 2012) | Prospective study | 8/2009-10/2010 | Brazil | CLSI | Single (530-bed tertiary safety net hospital) | Any infection | 4.0
(Trottier, et al., 2007) | Retrospective review | 1/2004-11/2005 | U.S. | Not reported | Single- BICU (Burn Intensive Care Unit) | Any infection | 9.0
(Zhou, et al., 2019) | Retrospective study | 1/2013-12/2017 | China | CLSI | Single (2,000 bed referral hospital) | Any infection | 7.0

Table C-21 Study Mortality Information, MDR A. baumannii

Reference | Mortality for Resistant Strain | Mortality for Susceptible Strain | Excess Mortality | p-value | Standard Error in Resistant-Strain Mortality
(Almomani, et al., 2015) | 42% | Not Studied | Not Studied | Not Studied | 5%
(Anunnatsiri & Tonsawan, 2011) | 92% | 48% | 44% | 0.001 | 6%
(Blanco, et al., 2018) | 24% | Not Studied | Not Studied | Not Studied | Unknown
(Brahmi, et al., 2007) | 68% | 47% | 21% | 0.004 | Unknown
(Brotfain, et al., 2017) | 29% | Not Studied | Not Studied | 0.003 | 4%
(Cornejo-Juárez, et al., 2020) | 50% | Not Studied | Not Studied | <.001 | 5%
(Daniels, et al., 2008) | 14% | 10% | 5% | 74.00% | 5%
(Daniels, et al., 2008) | 16% | 10% | 6% | 0.45 | 3%
(Fukuta, et al., 2013) | 42% | Not Studied | Not Studied | 0.2 | Unknown
(Guo, et al., 2016) | 59% | 4% | 55% | 0.003 | 6%
(Kuo, et al., 2007) | 49% | Not Studied | Not Studied | Not Studied | 7%
(Lee, et al., 2007) | 48% | 39% | 9% | 0.53 | 7%
(Liu, et al., 2015) | 29% | Not Studied | Not Studied | Not Studied | 3%
(Pierri, et al., 2016) | 57% | Not Studied | Not Studied | 0.6 | 13%
(Prata-Rocha, et al., 2012) | 43% | 33% | 10% | 0.28 | 7%
(Trottier, et al., 2007) | 31% | 25% | 6% | Not Studied | 9%
(Zhou, et al., 2019) | 59% | 13% | 46% | <0.001 | 3%

Table C-22 Study Length of Stay Information, MDR A. baumannii

Reference | Resistant Strain Sample Size | Susceptible Strain Sample Size | Resistant Strain LOS (Days) | Susceptible Strain LOS (Days) | Excess LOS (Days) | p-value
(Anunnatsiri & Tonsawan, 2011) | 24 | 25 | 21.5 | 14 | 7.5 | 0.18
(Brahmi, et al., 2007) | 29 | 34 | 27.3 | 32.3 | -5 | 0.2
(Brotfain, et al., 2017) | 129 | Not Studied | 48.02 | Not Studied | Not Studied | 0.028
(Cornejo-Juárez, et al., 2020) | 106 | Not Studied | 8 | Not Studied | Not Studied | 0.154
(Daniels, et al., 2008) | 146 | 42 | 32.5 | 26.5 | 6 | 0.11
(Fukuta, et al., 2013) | Not Studied | Not Studied | 28 | Not Studied | Not Studied | 0.001
(Lee, et al., 2007) | 46 | 46 | 54.2 | 34.1 | 20.1 | 0.006
(Pierri, et al., 2016) | 14 | Not Studied | 36 | Not Studied | Not Studied | 0.09
(Zhou, et al., 2019) | 274 | 64 | 29 | 22.5 | 6.5 | 0.015

Table C-23 General Study Information, Carbapenem-Resistant E. coli

Reference | Study Design | Enrollment Period | Country | Resistance Reference | Setting | Infection Site | Overall Score
(Ahn, et al., 2014) | Retrospective matched case-control study | 1/2006-12/2010 | South Korea | CLSI | Single (2000-bed tertiary care center) | Any infection | 6.0
(Budak, et al., 2014) | Prospective study | 6/2009-1/2011 | Turkey | Not Reported | Single (6 ICUs in 1,000 bed training hospital) | Any infection | 4.0
(Cai, et al., 2017) | Cohort study | 1/1/2009-12/31/2013 | U.S. | CLIA | Premier Healthcare Database | BSI; respiratory; urinary; other; any infection | 22.2
(Chang, et al., 2015) | Retrospective study | 1/2012-12/2012 | Taiwan | CLSI & EUCAST | Multi (9 medical centers and 8 regional hospitals) | Any infection | 5.0
(Ghafur, et al., 2014) | Retrospective analysis | 1/2012-12/2012 | India | Not Reported | Single (300-bed tertiary care specialty hospital) | BSI | 4.0
(Huang, et al., 2014) | Not listed | 1/2010-12/2011 | Taiwan | EUCAST & CLSI | Single (veterans general hospital) | Any infection | 4.0
(Marchaim, et al., 2011) | retrospective cohort study | 9/2008-8/2009 | U.S. | CLSI | Multi (8 tertiary referral hospitals with > 2,200 beds) | Any infection | 21.0
(Meng, et al., 2017) | Retrospective, matched case-controlcontrol, parallel study | 1/2012-12/2015 | China | EUCAST & CLSI | Single (3500-bed tertiary teaching hospital) | Any infection | 7.0

Table C-24 Study Mortality Information, Carbapenem-Resistant E. coli

Reference | Mortality for Resistant Strain | Mortality for Susceptible Strain | Excess Mortality | p-value | Standard Error in Resistant-Strain Mortality
(Ahn, et al., 2014) | 14% | 10% | 4% | 0.39 | 5%
(Cai, et al., 2017) | 16% | 9% | 7% | Not Reported | 7%
(Cai, et al., 2017) | 27% | 22% | 5% | Not Reported | 8%
(Cai, et al., 2017) | 7% | 4% | 3% | Not Reported | 2%
(Cai, et al., 2017) | 10% | 6% | 4% | Not Reported | 3%
(Cai, et al., 2017) | 10% | 5% | 5% | Not Reported | 2%
(Chang, et al., 2015) | 50% | Not Studied | Not Studied | Not Studied | 6%
(Ghafur, et al., 2014) | 64% | 38% | 25% | 0.008 | 7%
(Huang, et al., 2014) | 35% | 41% | -6% | 0.852 | 8%
(Marchaim, et al., 2011) | 37% | Not Studied | Not Studied | Not Studied | 5%
(Meng, et al., 2017) | 12% | 1% | 11% | 0.01 | 5%

Table C-25 Length of Stay Information, Carbapenem-Resistant E. coli

Reference | Resistant Strain Sample Size | Susceptible Strain Sample Size | Resistant Strain LOS (Days) | Susceptible Strain LOS (Days) | Excess LOS (Days) | p-value
(Ahn, et al., 2014) | 57 | 114 | 26.63 | 13.11 | 13.52 | <.05
(Budak, et al., 2014) | 13 | 95 | 57 | 30 | 27 | <.0001
(Chang, et al., 2015) | 66 | Not Studied | 36.2 | Not Studied | Not Studied | Not Studied
(Marchaim, et al., 2011) | 57 | Not Studied | 18.6 | Not Studied | N/A | Not Studied
(Meng, et al., 2017) | 49 | 98 | <6 month | <6 month | Not Studied | 0.06

Table C-26 General Study Information, Third-Generation Cephalosporin-Resistant E. coli

Reference | Study Design | Enrollment Period | Country | Resistance Reference | Setting | Infection Site | Overall Score
(Apisarnthanarak, et al., 2007) | Matched case-control study | 7/2003-6/2004 | Thailand | CLSI | Single (university hospital) | UTI, pneumonia, BSI | 5.0
(de Kraker, et al., 2011) | Prospective parallel matched cohort study | 7/2007-6/2008 | 13 European countries^39^ | Not Reported | Multi (13 tertiary hospitals, ranging from 819 to 2344 beds) | BSI | 16.0
(Fitzpatrick, et al., 2016) | Retrospective case-case-control study | 1/2012-12/2013 | U.S. | Not Reported | Multi (VA medical facilities throughout USA) | Any infection | 21.0
(Kang, et al., 2012) | Nationwide surveillance study | 10/2006-9/2007 | South Korea | CLSI | Multi (18 hospitals) | Any infection | 4.0
(Lee, et al., 2021) | Retrospective case-cohort Study | 1/2012-12/2016 | Australia | EUCAST | Multi (all hospitals in Queensland, totaling 134) | BSI; UTI | 7.3
(Lin, et al., 2019) | Retrospective observational study | 1/2005-12/2005 | Taiwan | CLSI & EUCAST | Single (2323-bed university tertiary-care teaching hospital) | Any infection | 5.0
(Mark, et al., 2021) | Retrospective cohort study | 1/2017-6/2019 | U.S. | Not Reported | Multi (21 Kaiser Permanente Northern California Eds) | UTI | 27.0
(Rodríguez-Baño, et al., 2010) | Case-controlcontrol study | 10/2004-1/2006 | Spain | CLSI | Multi (13 tertiary-care hospitals) | Any infection | 12.0
(Song, et al., 2009) | Retrospective matched case-control study | 1/2000-12/2006 | Korea | CLSI | Single (database at university hospital) | Liver cirrhosis and spontaneous bacterial peritonitis | 4.0
(Superti, et al., 2009) | Case-control study | 6/2004-3/2006 | Brazil | CLSI | Single (600-bed tertiary-care teaching hospital) | BSI | 5.0
(Trecarichi, et al., 2019) | Prospective cohort study | 1/2016-12/2017 | Italy | Not Reported | Multi (15 hematological wards of tertiary care centers or university hospitals) | BSI | 18.0
(Zhen, et al., 2020) | Retrospective study | 2013-2015 | China | CLSI | Multi (4 tertiary-case hospitals with 3200, 3500, 1727, & 2100 beds) | Any infection | 5.0

Table C-27 Study Mortality Information, Third-Generation Cephalosporin-Resistant E. coli

Reference | Mortality for Resistant Strain | Mortality for Susceptible Strain | Excess Mortality | p-value | Standard Error in Resistant-Strain Mortality
(Apisarnthanarak, et al., 2007) | 35% | 16% | 19% | <.05 | 6%
(de Kraker, et al., 2011) | 32% | 17% | 16% | <.01 | 5%
(Fitzpatrick, et al., 2016) | 2% | 5% | -3% | Not Reported | 1%
(Kang, et al., 2012) | 45% | 14% | 31% | <.001 | 9%
(Lee, et al., 2021) | 16% | 17% | -1% | Not Reported | 5%
(Lee, et al., 2021) | 3% | 5% | -2% | Not Reported | 1%
(Lin, et al., 2019) | 16% | 8% | 8% | 0.005 | 3%
(Mark, et al., 2021) | 12% | 8% | 4% | Not Reported | 1%
(Rodríguez-Baño, et al., 2010) | 17% | 8% | 9% | 2.00% | 4%
(Song, et al., 2009) | 46% | 14% | 32% | 0.001 | 10%
(Superti, et al., 2009) | 51% | 30% | 21% | 0.019 | 7%
(Trecarichi, et al., 2019) | 14% | 5% | 9% | 0.004 | 4%
(Zhen, et al., 2020) | 3% | 2% | 1% | 0.281 | Unknown

Table C-28 Study Length of Stay Information, Third-Generation Cephalosporin-Resistant E. coli

Reference | Resistant Strain Sample Size | Susceptible Strain Sample Size | Resistant Strain LOS (Days) | Susceptible Strain LOS (Days) | Excess LOS (Days) | p-value
(Apisarnthanarak, et al., 2007) | 74 | 74 | 22.5 | 17.5 | 5 | <.05
(de Kraker, et al., 2011) | 111 | 1110 | 12 | 10 | 2 | <.05 & <.01, respectively
(Fitzpatrick, et al., 2016) | 492 | Not Studied | 22 | Not Studied | Not Studied | Not Studied
(Lee, et al., 2021) | 45 | 543 | 24 | 22 | 2 | Not Reported
(Lee, et al., 2021) | 448 | 8504 | 19 | 18 | 1 | Not Reported
(Lin, et al., 2019) | 133 | 543 | 18 | 14 | 4 | <.001
(Mark, et al., 2021) | 530 | 3577 | 88.8 | 67.2 | 21.6 | Not Reported
(Superti, et al., 2009) | 51 | 94 | 26 | 16 | 10 | 0.002

Table C-29 General Study Information, Fluoroquinolone-Resistant E. coli

Reference | Study Design | Enrollment Period | Country | Resistance Reference | Setting | Infection Site | Overall Score
(Brigmon, et al., 2015) | Retrospective cohort study | 1/2010-12/2012 | U.S. | CLSI | Multi (two hospitals with combined capacity of >1,100 beds). | BSI | 22.5
(Camins, et al., 2011) | Retrospective case-control study | 1/2000-12/2005 | U.S. | Not Reported | Single (1250-bed tertiary academic medical center) | BSI | 18.0
(Kadri, et al., 2018) | Retrospective cohort analysis | 2009-2013 | U.S. | Not Reported | Multi (173 hospitals) | BSI | 24.0
(Ortega, et al., 2009) | Analysis of cases prospectively collected through surveillance program | 1/1991-12/2007 | Spain | CLSI | Single (700 bed university tertiary center) | BSI | 12.0
(Suzuki, et al., 2019) | Matched cohort study | 1/2003-12/2013 | U.S. | Not Reported | Multi (129 Veteran Health Administration hospitals) | Hospital-onset BSI | 18.0
(van der Starre, et al., 2011) | Nested case-control study | 1/2004 – 12/2009 | Netherlan ds | EUCAST | Multi (7 hospitals) | UTI | 12.0

Table C-30 Study Mortality Information, Fluoroquinolone-Resistant E. coli

Reference | Mortality for Resistant Strain | Mortality for Susceptible Strain | Excess Mortality | p-value | Standard Error in Resistant-Strain Mortality
(Brigmon, et al., 2015) | 19% | 12% | 7% | 0.1 | 4%
(Camins, et al., 2011) | 26% | 8% | 18% | 0.002 | 5%
(Kadri, et al., 2018) | 18% | Not Studied | Not Studied | Not Studied | 1%
(Ortega, et al., 2009) | 12% | 8% | 4% | <.001 | 1%
(Suzuki, et al., 2019) | 38% | 26% | 11% | Not Reported | 3%
(van der Starre, et al., 2011) | 18% | 11% | 7% | Not Reported | 5%

Table C-31 Study Length of Stay Information, Fluoroquinolone-Resistant E. coli

Reference | Resistant Strain Sample Size | Susceptible Strain Sample Size | Resistant Strain LOS (Days) | Susceptible Strain LOS (Days) | Excess LOS (Days) | p-value
(Brigmon, et al., 2015) | 90 | 384 | 11.6 | 9.3 | 2.3 | 0.03
(Camins, et al., 2011) | 93 | 93 | 9 | 6 | 3 | 0.002

Table C-32 General Study Information, MDR E. coli

Reference | Study Design | Enrollment Period | Country | Resistance Reference | Setting | Infection Site | Overall Score
(de Laroche, et al., 2021) | Retrospective cohort study | 4/2010-12/2016 | France | EUCAST | Single (524 bed-university hospital) | Any infection | 14.0
(Gudiol, et al., 2011) | Prospective observational study | 1/2006-12/2009 | Spain | CLSI | Single (200-bed university referral cancer center) | Any infection | 10.0
(Hristea, et al., 2011) | Retrospective study | 1/2009-1/2011 | Romania | CLSI | Not Reported | BSI | 10.0
(Karve, et al., 2018) | Retrospective cohort study | 7/2013-6/2014 | Brazil, France, Italy, Russia, Spain | Not Reported | Multi-center | UTI | 18.0
(Kumar, et al., 2018) | Prospective study | 2013-2015 | India | CLSI | Single (800-bed tertiary-care hospital) | Pneumonia | 7.0
(Majangara, et al., 2018) | Prospective descriptive cohort study | 11/2014-7/2015 | Zimbabwe | Not Reported | Multi-center | Female genital tract & BSI | 7.0
(Mauldin, et al., 2010) | Retrospective | 1/2000-6/2008 | U.S. | Not Reported | Single | Any infection | 24.0
(Nemeth, et al., 2012) | Retrospective study | 1/2009-11/2011 | Switzerland | Not Reported | Single (university hospital) | Any infection | 11.0
(Parveen, et al., 2015) | Retrospective study | 12/2012-11/2013 | Pakistan | CLSI | Single (cancer hospital and research center) | Any infection | 5.0
(Peralta, et al., 2007) | Retrospective cohort study | 1/1997-6/2005 | Spain | CLSI | Single (250-bed adult acute-care community teaching hospital) | BSI | 13.0
(Tseng, et al., 2018) | Retrospective cohort study | 2009 | Taiwan | Not Reported | Single-center (2200-bed teaching hospital providing both primary and tertiary care) | Any infection | 8.0
(Tu, et al., 2020) | Retrospective study | 1/2015-12/2018 | China | CLSI | Multi (2 hospitals) | Not specified | 7.0

Table C-33 Study Mortality Information, MDR E. coli

Reference | Mortality for Resistant Strain | Mortality for Susceptible Strain | Excess Mortality | p-value | Standard Error in Resistant-Strain Mortality
(de Laroche, et al., 2021) | 28% | 17% | 11% | Not Significant | 7%
(Gudiol, et al., 2011) | 39% | 20% | 19% | 0.003 | 7%
(Hristea, et al., 2011) | 26% | 13% | 13% | 0.070 | 7%
(Karve, et al., 2018) | 40% | 30% | 10% | Not Reported | 4%
(Kumar, et al., 2018) | 29% | Not Studied | Not Studied | Not Significant | 5%
(Majangara, et al., 2018) | 17% | 6% | 10% | 0.19 | 11%
(Nemeth, et al., 2012) | 11% | 2% | 9% | 0.018 | 5%
(Parveen, et al., 2015) | 45% | 28% | 17% | Not Reported | 5%
(Peralta, et al., 2007) | 14% | 4% | 10% | Not Reported | 4%
(Tu, et al., 2020) | 33% | 19% | 15% | 0.021 | 4%

Table C-34 Study Length of Stay Information, MDR E. coli

Reference | Resistant Strain Sample Size | Susceptible Strain Sample Size | Resistant Strain LOS (Days) | Susceptible Strain LOS (Days) | Excess LOS (Days) | p-value
(Majangara, et al., 2018) | 15 | 114 | 23 | 10.5 | 12.5 | 0.009
(Mauldin, et al., 2010) | 103 | 559 | 47 | 30 | 17 | 0.0001
(Nemeth, et al., 2012) | 46 | 213 | 8 | 3.5 | 4.5 | 0.011
(Peralta, et al., 2007) | 87 | 576 | 17.01 | 12.15 | 4.86 | 0.03
(Tseng, et al., 2018) | 125 | 692 | 19 | 9 | 10 | 0.001

Table C-35 General Study Information, Carbapenem-Resistant K. pneumoniae

Reference | Study Design | Enrollment Period | Country | Resistance Reference | Setting | Infection Site | Overall Score
(Ben-David, et al., 2012) | Retrospective cohort study | 1/2006-12/2006 | Israel | CLSI | Not extracted | BSI | 5.0
(Brizendine, et al., 2015) | Retrospective cohort study | 2006-2012 | U.S. | Not Reported | Not extracted | UTI | 18.0
(Cai, et al., 2017) | Cohort study | 1/1/2009-12/31/2013 | U.S. | CLIA | Not extracted | BSI; respiratory; urinary; other; any infection | 24.0
(Ulu, et al., 2015) | Retrospective cohort | 1/2012-12/2012 | Turkey | Not Reported | Single center, ICUs | Any infection | 14.0
(Cober, et al., 2013) | Retrospective cohort study | 2006-2009 | U.S. | Not Reported | Not extracted | BSI | 18.0
(Cubero, et al., 2015) | Retrospective cohort study | 1/2010-12/2012 | Spain | EUCAST | Not extracted | Any infection | 12.0
(Daikos, et al., 2009) | Prospective observational study | 2/2005-3/2006 | Greece | CLSI | Not extracted | BSI | 6.0
(Gaviria, et al., 2011) | Retrospective matched case-control study | 4/2009-12/2011 | U.S. | CLSI | Not extracted | Not determined | 18.0
(Falagas, et al., 2007) | Retrospective matched case-control study | 1/2000-5/2006 | Greece | Not Reported | Multicenter (2 hospitals) | Any infection | 10.0
(Gasink, et al., 2009) | Case-control study | 1/2006-4/2008 | U.S. | Not Reported | Not extracted | Any infection | 18.0
(Giannella, et al., 2015) | Prospective cohort | 6/2010-12/2013 | Italy | Not Reported | Single Center | BSI and pneumonia | 12.0
(Hauck, et al., 2016) | Prospective cohort | 12/2011-10/2014 | U.S. | Not Reported | Multicenter (5 health systems) | BSI; UTI; pneumonia | 25.0
(Hoxha, et al., 2016) | Prospective cohort | 12/2012-7/2013 | Italy | Not Reported | Multicenter (10 Italian hospitals) | BSI and pneumonia | 14.0
(Hu, et al., 2016) | Case-control | 1/2011-6/2013 | China | Not determined | Single center, a 67-bed ICU | Any infection | 6.0
(Hussein, et al., 2013) | Retrospective case-control study | 1/2006-12/2008 | Israel | CLSI | Single center | BSI | 6.0
(Kadri, et al., 2019) | Retrospective matched case-control study | 1/2010-12/2013 | U.S. | Not Reported | Not extracted | BSI; UTI; pneumonia | 16.5
(Liu, et al., 2012) | Matched case-control study | 1/2007-12/2009 | Taiwan | CLSI | Not extracted | BSI | 5.0
(Correa, et al., 2013) | Matched case-control study | 1/2006-8/2008 | Brazil | CLSI | Not extracted | BSI, SSI, UTI, skin and soft tissue | 5.0
(Mouloudi, et al., 2010) | Retrospective nested case-control study | 1/2007-12/2008 | Greece | CLSI | Not extracted | BSI | 10.0
(Ny, et al., 2015) | Retrospective cohort study | 1/2011-12/2013 | U.S. | Not Reported | Not extracted | UTI and pneumonia; pneumonia | 20.0
(Orsi, et al., 2011) | Retrospective case-control study | 7/2008-12/2009 | Italy | EUCAST | Not extracted | Not determined | 10.0
(Orsi, et al., 2013) | Case-control study | 7/2008-6/2011 | Italy | EUCAST | Not extracted | Not determined | 12.0
(Pan, et al., 2019) | Retrospective cohort | 2014 | China | Not Reported | Single center | Not determined | 8.0
(Patel, et al., 2008) | Retrospective matched case-control study | 7/2004-6/2006 | U.S. | CLSI | Single center | Not determined | 15.0
(Pouch, et al., 2015) | Nested case-control study | 1/2007-12/2010 | U.S. | CLSI | Not extracted | UTI | 15.0
(Schwaber, et al., 2008) | Retrospective cohort study | 2003-2006 | Israel | CLSI | Not extracted | Any infection | 5.0
(Simkins, et al., 2014) | Retrospective case-control study | 1/2006-12/2010 | U.S. | Not Reported | Single center | Not determined | 15.0
(Vardakas, et al., 2015) | Retrospective cohort study | 1/2006-1/2009 | Greece | CLSI | Single center, an 8-bed ICU | BSI | 14.0
(Rueda & Tobón, 2014) | Case-case-control study | 1/2008-1/2011 | Colombia | CLSI | Not extracted | Any infection | 6.0
(Wang, et al., 2018) | Case-control | 1/2010-12/2014 | China | Not Reported | Single center | Any infection | 7.0

Table C-36 Study Mortality Information, Carbapenem-Resistant K. pneumoniae

Reference | Mortality for Resistant Strain | Mortality for Susceptible Strain | Excess Mortality | p-value | Standard Error in Resistant-Strain Mortality
(Ben-David, et al., 2012) | 69% | 30% | 39% | <0.001 | 7%
(Brizendine, et al., 2015) | 18% | 2% | 17% | Not Reported | 8%
(Cai, et al., 2017) | 38% | 14% | 25% | Not Reported | 3%
(Cai, et al., 2017) | 26% | 20% | 6% | Not Reported | 1%
(Cai, et al., 2017) | 10% | 6% | 3% | Not Reported | 2%
(Cai, et al., 2017) | 16% | 8% | 8% | Not Reported | 1%
(Cai, et al., 2017) | 21% | 12% | 9% | Not Reported | 1%
(Cober, et al., 2013) | 42% | 15% | 27% | 0.005 | 11%
(Cubero, et al., 2015) | 40% | 11% | 29% | Not Reported | 11%
(Daikos, et al., 2009) | 43% | 17% | 26% | Not Reported | 13%
(Gaviria, et al., 2011) | 5% | 8% | -3% | Not Reported | 5%
(Falagas, et al., 2007) | 30% | 34% | -4% | Not Reported | 6%
(Gasink, et al., 2009) | 32% | 10% | 22% | Not Reported | 6%
(Hoxha, et al., 2016) | 61% | 20% | 41% | Not Reported | 7%
(Hussein, et al., 2013) | 44% | 29% | 15% | Not Reported | 5%
(Kadri, et al., 2019) | Not Studied | Not Studied | 5% | Not Studied | Unknown
(Kadri, et al., 2019) | 36% | Not Studied | 11% | p<0.001 | 2%
(Kadri, et al., 2019) | 35% | 20% | 16% | p<0.0001 | 1%
(Kadri, et al., 2019) | 29% | 17% | 13% | Not Reported | Unknown
(Liu, et al., 2012) | 60% | 40% | 20% | 0.102 | 10%
(Correa, et al., 2013) | 50% | 28% | 23% | 0.085 | 11%
(Mouloudi, et al., 2010) | 68% | 41% | 27% | 0.03 | 8%
(Ny, et al., 2015) | 15% | 10% | 4% | 0.76 | 5%
(Ny, et al., 2015) | 29% | 15% | 15% | 0.14 | 7%
(Ny, et al., 2015) | 24% | 14% | 10% | 0.31 | 9%
(Orsi, et al., 2011) | 39% | 28% | 11% | Not Reported | 9%
(Orsi, et al., 2013) | 38% | 28% | 11% | Not Reported | 6%
(Patel, et al., 2008) | 48% | 20% | 28% | <0.001 | 5%
(Pouch, et al., 2015) | 30% | 10% | 20% | 0.03 | 10%
(Schwaber, et al., 2008) | 44% | 13% | 31% | Not Reported | 7%
(Simkins, et al., 2014) | 46% | 8% | 38% | 0.005 | 14%
(Vardakas, et al., 2015) | 73% | 58% | 14% | 0.19 | 5%
(Rueda & Tobón, 2014) | 51% | 33% | 18% | Not Reported | 6%

Table C-37 Study Length of Stay Information, Carbapenem-Resistant K. pneumoniae

Reference | Resistant Strain Sample Size | Susceptible Strain Sample Size | Resistant Strain LOS (Days) | Susceptible Strain LOS (Days) | Excess LOS (Days) | p-value
(Ulu, et al., 2015) | 47 | 51 | 37.3 | 29.94 | 7.36 | 0.026
(Giannella, et al., 2015) | 20 | 217 | 99.5 | 17 | 82.5 | <0.001
(Hauck, et al., 2016) | 90 | 223 | 14 | 9 | 5 | <0.01
(Hauck, et al., 2016) | 121 | 223 | 10 | 9 | 1 | 0.76
(Hauck, et al., 2016) | 49 | 223 | 19 | 9 | 10 | <0.0001
(Hu, et al., 2016) | 65 | 65 | 33.49 | 30.98 | 2.51 | 0.561
(Pan, et al., 2019) | 66 | 132 | 46 | 23 | 23 | Not Studied
(Wang, et al., 2018) | 48 | 48 | 84 | 33 | 51 | 0.097

Table C-38 General Study Information, Third-Generation Cephalosporin-Resistant K. pneumoniae

Reference | Study Design | Enrollment Period | Country | Resistance Reference | Setting | Infection Site | Overall Score
(Apisarnthanarak, et al., 2007) | Matched case-control study | 7/2003-6/2004 | Thailand | CLSI | Single (university hospital) | Any infection | 4.0
(Fitzpatrick, et al., 2016) | Retrospective case-case-control study | 1/2012-12/2013 | U.S. | Not Reported | Single (Veterans’ Affairs med center) | Any infection | 19.5
(Gallagher, et al., 2014) | Retrospective case-case-control study | 1/2005-10/2010 | U.S. | CLSI | Single (university hospital) | BSI | 18.0
(Kang, et al., 2012) | Post-hoc analysis of nationwide surveillance studies | 10/2006-11/2007 | South Korea | CLSI | Multi (18 hospitals) | Any infection | 4.0
(Li, et al., 2014) | Retrospective study | 1/2009-12/2011 | China | CLSI | Single (university cancer institute & hospital with 2,400 beds) | BSI | 4.0
(Mark, et al., 2021) | Retrospective cohort study | 1/2017-6/2019 | U.S. | Not Reported | 21 emergency departments | UTI | 27.0
(Martelius, et al., 2016) | Prospective study | 1999-2013 | Finland | CLSI | Multi (17 acute care hospitals nationwide) | BSI | 12.0
(Mosqueda-Gómez, et al., 2008) | Retrospective case-control study | 1/1993-12/2002 | Mexico | CLSI | Single (250-bed referral hospital) | BSI | 4.0
(Seboxa, et al., 2015) | Retrospective study | 2012-2013 | Ethiopia | CLSI | Single (tertiary teaching hospital) | BSI | 4.0
(Superti, et al., 2009) | Case-control study | 6/2004-3/2006 | Brazil | CLSI | Single (600 bed tertiary-care teaching hospital) | BSI | 5.0
(Tsui, et al., 2012) | Retrospective study | 1/2006-12/2009 | Taiwan | CLSI | Single | Any infection | 4.0
(Zhen, et al., 2020) | Retrospective study | 2013-2015 | China | CLSI | Multi (4 tertiary-care hospitals, with 3,200, 3,500, 1,727, and 2,100 beds) | Any infection | 7.0

Table C-39 Study Mortality Information, Third-Generation Cephalosporin-Resistant K. pneumoniae

Reference | Mortality for Resistant Strain | Mortality for Susceptible Strain | Excess Mortality | p-value | Standard Error in Resistant-Strain Mortality
(Apisarnthanarak, et al., 2007) | 35% | 16% | 19% | >.05 | 6%
(Fitzpatrick, et al., 2016) | 2% | 2% | 0% | 1.000 | 1%
(Gallagher, et al., 2014) | 32% | Not Studied | Not Studied | Not Studied | Unknown
(Kang, et al., 2012) | 45% | 14% | 31% | <.001 | 9%
(Li, et al., 2014) | 27% | 18% | 9% | 0.431 | Unknown
(Mark, et al., 2021) | 12% | 8% | 4% | Not Studied | 1%
(Martelius, et al., 2016) | 14% | 12% | 2% | 0.42 | 3%
(Mosqueda-Gómez, et al., 2008) | 35% | 27% | 8% | 47.00% | Unknown
(Seboxa, et al., 2015) | 100% | 11% | 89% | 0.020 | Unknown
(Superti, et al., 2009) | 51% | 30% | 21% | 0.019 | 7%
(Tsui, et al., 2012) | 21% | Not Studied | Not Studied | 0.27 | 8%
(Zhen, et al., 2020) | 7% | 4% | 3% | <.000 | 1%

Table C-40 Study Length of Stay Information, Third-Generation Cephalosporin-Resistant K. pneumoniae

Reference | Resistant Strain Sample Size | Susceptible Strain Sample Size | Resistant Strain LOS (Days) | Susceptible Strain LOS (Days) | Excess LOS (Days) | p-value
(Apisarnthanarak, et al., 2007) | 74 | 74 | 22.5 | 17.5 | 5 | <.05
(Fitzpatrick, et al., 2016) | 492 | 492 | 22 | 11 | 11 | 0.001
(Gallagher, et al., 2014) | 111 | Not Studied | 63 | Not Studied | Not Studied | Not Studied
(Mark, et al., 2021) | 530 | 3577 | 4.8 | 3.6 | 1.2 | Not Reported
(Mosqueda-Gómez, et al., 2008) | 17 | 104 | 20.9 | 15.9 | 5 | 0.49
(Superti, et al., 2009) | 51 | 94 | 26 | 16 | 10 | Not Reported
(Zhen, et al., 2020) | 1617 | 1617 | 31 | 20 | 11 | <.000

Table C-41 General Study Information, Fluoroquinolone-Resistant K. pneumoniae

Reference | Study Design | Enrollment Period | Country | Resistance Reference | Setting | Infection Site | Overall Score
(Brigmon, et al., 2015) | Retrospective cohort study | 1/2010 - 12/2012 | U.S. | Not Reported | Single health system (>1100 beds) | BSI | 22.5
(Kadri, et al., 2018) | Retrospective cohort study | 2009 - 2013 | U.S. | Not Reported | Multi (173 US hospitals) | BSI | 24.0
(Suzuki, et al., 2019) | Matched cohort study | 1/2003-12/2013 | U.S. | Not Reported | Multi (129 Veteran Health Administration hospitals) | Hospital-Onset BSI | 24.0

Table C-42 Study Mortality Information, Fluoroquinolone-Resistant K. pneumoniae

Reference | Mortality for Resistant Strain | Mortality for Susceptible Strain | Excess Mortality | p-value | Standard Error in Resistant-Strain Mortality
(Brigmon, et al., 2015) | 19% | 12% | 7% | 0.1 | Unknown
(Kadri, et al., 2018) | 18% | Not Studied | Not Studied | Not Studied | 1%
(Suzuki, et al., 2019) | 38% | 26% | 11% | Not Reported | 3%

Table C-43 Study Length of Stay Information, Fluoroquinolone-Resistant K. pneumoniae

Reference | Resistant Strain Sample Size | Susceptible Strain Sample Size | Resistant Strain LOS (Days) | Susceptible Strain LOS (Days) | Excess LOS (Days) | p-value
(Brigmon, et al., 2015) | 90 | 384 | 11.6 | 9.3 | 2.3 | 0.03

Table C-44 General Study Information, MDR K. pneumoniae

Reference | Study Design | Enrollment Period | Country | Resistance Reference | Setting | Infection Site | Overall Score
(Amanati, et al., 2021) | Retrospective study | 7/2015-8/2019 | Iran | CLSI | Single (educational 100-bed inpatient center) | BSI | 5.0
(Chittawatanarat, et al., 2014) | Retrospective analysis | 1/2008-12/2012 | Thailand | Not Reported | Single (21 bed general surgical ICU at 1,400 bed tertiary-care university based hospital) | Respiratory | 4.0
(Gandra, et al., 2019) | Retrospective observational study | 1/2015-12/2015 | India | CLSI | Multi (10 tertiary and quaternary referral hospitals, each ranging in size from 120 to 350 beds) | Any infection | 5.0
(Garnica, et al., 2009) | Retrospective case-control study | 7/1994-1/2005 | Brazil | Not Reported | Single | Any infection | 4.0
(Khairy, et al., 2020) | Cross-sectional study | 3/2017-6/2017 | Egypt | Not Reported | Multi (2 hospitals: an 800-bed adult and pediatric teaching hospital and a 120-bed tertiary care hospital) | Multiple infections | 5.0
(Liu, et al., 2020) | Retrospective study | 1/2012-5/2018 | China | CLSI | Multi (11 teaching hospitals) | Any infection | 6.0
(Michalopoulos, et al., 2011) | Retrospective cohort study | 1/2005-12/2007 | Greece | CLSI | Single (24-bed ICU at tertiary care hospital) | BSI | 12.0
(Ning, et al., 2019) | Prospectively maintained database study | 1/2010-5/2019 | China | Reported as “the standard protocol” | Single (a large tertiary-care hospital) | BSI | 6.5
(Siwakoti, et al., 2018) | Prospective cohort study | 7/2017-12/2017 | Nepal | CLSI | Single (7-bed general ICU) | Multiple infections | 8.0

Table C-45 Study Mortality Information, MDR K. pneumoniae

Reference | Mortality for Resistant Strain | Mortality for Susceptible Strain | Excess Mortality | p-value | Standard Error in Resistant-Strain Mortality
(Amanati, et al., 2021) | 20% | Not Studied | Not Studied | Not Studied | Unknown
(Chittawatanarat, et al., 2014) | 30% | 19% | 11% | 0.02 | 10%
(Gandra, et al., 2019) | 18% | Not Studied | Not Studied | Not Reported | Unknown
(Garnica, et al., 2009) | 40% | Not Studied | Not Studied | 0.03 | Unknown
(Liu, et al., 2020) | 33% | 28% | 5% | 0.267 | 5%
(Michalopoulos, et al., 2011) | 48% | 19% | 29% | 0.01 | 8%
(Ning, et al., 2019) | 35% | 11% | 24% | 0.00% | 5%
(Siwakoti, et al., 2018) | 38% | 20% | 18% | 0.007 | 6%

Table C-46 Study Length of Stay Information, MDR K. pneumoniae

Reference | Resistant Strain Sample Size | Susceptible Strain Sample Size | Resistant Strain LOS (Days) | Susceptible Strain LOS (Days) | Excess LOS (Days) | p-value
(Khairy, et al., 2020) | 42 | 208 | 8.14 | Not Studied | Not Studied | Not Studied
(Ning, et al., 2019) | 108 | 80 | 67.7 | 51.2 | 16.5 | 0.001
(Siwakoti, et al., 2018) | 64 | 10 | 14 | 9 | 5 | 0.93

Table C-47 General Study Information, Carbapenem-Resistant P. aeruginosa

Reference | Study Design | Enrollment Period | Country | Resistance Reference | Setting | Infection Site | Overall Score
(Aviv, et al., 2018) | Retrospective matched case-case-control analysis | 2007-2012 | Israel | CLSI | Single | BSI | 6.0
(Balkhair, et al., 2019) | Retrospective study | 1/2007-12/2016 | Oman | CLSI | Single (600 bed teaching and referral hospital) | BSI | 6.0
(Cai, et al., 2017) | Cohort study | 1/1/2009-12/31/2013 | U.S. | CLIA | Premier Healthcare Database | BSI; respiratory; urinary; other; any infection | 24.0
(Chaves, et al., 2017) | Case-control study | 12/2011-1/2013 | Brazil | CLSI | Single-center (12-room unit in 1000-bed tertiary-care hospital) | BSI | 5.0
(Chen, et al., 2019) | Retrospective propensity score-matched cohort | 2/2014-3/2018 | China | CLSI | Single | Any infection | 9.0
(Crusio, et al., 2014) | Prospective observational cohort study | 11/2009-11/2010 | U.S. | CLSI | Single (700-bed community teaching hospital) | Any infection | 18.0
(Dantas, et al., 2014) | Retrospective study | 5/2009 - 8/2011 | Brazil | Not Reported | Single (530-bed tertiary-care university hospital) | BSI | 5.0
(de Souza, et al., 2021) | Retrospective cohort study | 11/2015-10/2016 | Brazil | CLSI | Single (ICU at 237-bed public tertiary care hospital) | Any infection | 7.0
(Djordjevic, et al., 2013) | Prospective cohort study | 1/2009-12/2011 | Serbia | Not Reported | Single (large hospital) | Any infection | 16.0
(Huang, et al., 2019) | Retrospective study | 1/2015-12/2015 | Taiwan | CLSI | Single-center (2900-bed medical center and teaching hospital) | Any infection | 5.0
(Jeong, et al., 2014) | Retrospective cohort study | 1/2007-12/2009 | South Korea | CLSI | Single (2000 bed teaching hospital) | BSI | 7.0
(Lin, et al., 2016) | Retrospective cohort study | 2000-2010 | Taiwan | CLSI | Multi (5 hospitals) | Any infection | 8.0
(Luyt, et al., 2014) | Prospective, observational study | Not Reported | France | EUCAST | Single (2 ICU wards in a hospital) | LRTI | 8.0
(Meradji, et al., 2015) | Retrospective case-control study | 1/2012 - 12/2013 | Algeria | CLSI | Multi (3 hospitals) | Any infection | 5.0
(Papadimitriou-Olivgeris, et al., 2019) | Retrospective cohort study | 2012-2016 | Greece | EUCAST | Single (ICU at university general hospital) | BSI | 18.0
(Peña, et al., 2012) | Prospective cohort study | 1/2007-12/2009 | Spain | CLSI | Multi (10 public hospitals in four areas of Spain) | BSI | 16.0
(Rossi, et al., 2017) | Case-control study | 5/2009-12/2012 | Brazil | CLSI | Single | Any infection | 6.0
(Suárez, et al., 2010) | Retrospective cohort study | 1/2005-12/2005 | Spain | CLSI | Single (900 bed tertiary-care teaching hospital) | BSI | 10.0
(Tofas, et al., 2017) | Case-control study | 1/2012-12/2014 | Greece | CLSI | Multi (3 hospitals) | BSI | 12.0
(Tuon, et al., 2012) | Case-control study | 2/2006-1/2009 | Brazil | CLSI | Single (660 bed tertiary-care hospital) | BSI | 5.0
(Zhang, et al., 2018) | Retrospective study | 1/2014 - 6/2016 | China | CLSI | Single | Any infection | 7.0

Table C-48 Study Mortality Information, Carbapenem-Resistant P. aeruginosa

Reference | Mortality for Resistant Strain | Mortality for Susceptible Strain | Excess Mortality | p-value | Standard Error in Resistant-Strain Mortality
(Aviv, et al., 2018) | 53% | 54% | -1% | 0.9 | 5%
(Balkhair, et al., 2019) | 80% | 22% | 59% | 0 | 6%
(Cai, et al., 2017) | 33% | 20% | 13% | Not Reported | 3%
(Cai, et al., 2017) | 21% | 15% | 6% | Not Reported | 1%
(Cai, et al., 2017) | 10% | 6% | 4% | Not Reported | 1%
(Cai, et al., 2017) | 17% | 7% | 10% | Not Reported | 1%
(Cai, et al., 2017) | 17% | 10% | 7% | Not Reported | 0%
(Chaves, et al., 2017) | 79% | Not Studied | Not Studied | Not Reported | Unknown
(Chen, et al., 2019) | 13% | 8% | 5% | 0.044 | 2%
(Crusio, et al., 2014) | 50% | Not Studied | Not Studied | Not Reported | Unknown
(Dantas, et al., 2014) | 47% | 37% | 10% | 0.33 | 7%
(de Souza, et al., 2021) | 39% | Not Studied | Not Studied | Not Reported | Unknown
(Huang, et al., 2019) | 41% | Not Studied | Not Studied | Not Reported | 12%
(Jeong, et al., 2014) | 68% | 27% | 41% | Not Reported | 6%
(Lin, et al., 2016) | 22% | 20% | 2% | 0.925 | 5%
(Luyt, et al., 2014) | 37% | 31% | 6% | Not Reported | 6%
(Meradji, et al., 2015) | 13% | 2% | 12% | 0.09 | 9%
(Papadimitriou-Olivgeris, et al., 2019) | 26% | 13% | 13% | 0.004 | 4%
(Peña, et al., 2012) | 35% | 27% | 8% | 0.06 | 4%
(Rossi, et al., 2017) | 70% | 50% | 20% | 1.65% | 6%
(Suárez, et al., 2010) | 33% | 30% | 4% | 0.69 | 8%
(Tofas, et al., 2017) | 47% | 31% | 16% | 0.26 | 11%
(Tuon, et al., 2012) | 45% | 54% | -9% | 0.288 | 9%
(Zhang, et al., 2018) | 9% | 4% | 6% | 0 | 2%

Table C-49 Study Length of Stay Information, Carbapenem-Resistant P. aeruginosa

Reference | Resistant Strain Sample Size | Susceptible Strain Sample Size | Resistant Strain LOS (Days) | Susceptible Strain LOS (Days) | Excess LOS (Days) | p-value
(Aviv, et al., 2018) | 85 | 85 | 37 | 35 | 2 | 0.932
(Chaves, et al., 2017) | 29 | 58 | 35.1 | 43.6 | -8.5 | 0.12
(Chen, et al., 2019) | 270 | 270 | 29 | 25.5 | 3.5 | 0.026
(Crusio, et al., 2014) | 11 | Not Studied | 51 | Not Studied | Not Studied | Not Studied
(Dantas, et al., 2014) | 55 | 65 | 48 | 41 | 7 | 0.65
(de Souza, et al., 2021) | 28 | Not Studied | 34.4 | Not Studied | Not Studied | Not Studied
(Djordjevic, et al., 2013) | 167 | 94 | 34.17 | 30.69 | 3.48 | 0.083
(Jeong, et al., 2014) | 63 | 179 | 52.7 | Not Studied | 52.7 | 0.635
(Luyt, et al., 2014) | 68 | 101 | 37 | 29 | 8 | Not Reported
(Meradji, et al., 2015) | 15 | 65 | 82.5 | 63.44 | 19.06 | 0.04
(Rossi, et al., 2017) | 69 | 88 | 60 | 65.70125 | -5.69125 | 0.3477
(Suárez, et al., 2010) | 33 | 88 | 19 | 9 | 10 | 0.03
(Tuon, et al., 2012) | 29 | 48 | 43 | 43.1 | -0.1 | 0.987
(Zhang, et al., 2018) | 264 | 624 | 31.67 | 22.33 | 9.34 | 0

Table C-50 General Study Information, Third-Generation Cephalosporin-Resistant P. aeruginosa

Reference | Study Design | Enrollment Period | Country | Resistance Reference | Setting | Infection Site | Overall Score
(Akhabue, et al., 2011) | Case-control study | 1/2001-12/2006 | U.S. | CLSI | Multi (725-bed tertiary care center and 344-bed urban community hospital) | Any infection | 18.0
(Dantas, et al., 2014) | Retrospective study | 5/2009-8/2011 | Brazil | CLSI | Single (530-bed tertiary-care university hospital) | Any infection | 5.0
(Joo, et al., 2011) | Retrospective cohort study | 10/2006-3/2009 | Korea | CLSI | Single (1,900 bed tertiary care university hospital) | Any infection | 7.0
(Picot-Guéraud, et al., 2015) | Monocentric retrospective observational cohort study | 1/2011-12/2013 | France | CLSI | Single (university hospital w/ 2,200 acute and long-term beds) | Any infection | 12.0
(Su, et al., 2015) | Retrospective study | 1/2006-12/2011 | Taiwan | CLSI | Single (3715-bed university-affiliated tertiary care w/ 308 ICU beds | BSI | 5.0

Table C-51 Study Mortality Information, Third-Generation Cephalosporin-Resistant P. aeruginosa

Reference | Mortality for Resistant Strain | Mortality for Susceptible Strain | Excess Mortality | p-value | Standard Error in Resistant-Strain Mortality
(Akhabue, et al., 2011) | 20% | 13% | 7% | 0.007 | 3%
(Dantas, et al., 2014) | 48% | 41% | 8% | 0.550 | 6%
(Joo, et al., 2011) | 38% | 18% | 20% | 0.0002 | 6%
(Picot-Guéraud, et al., 2015) | 18% | Not studied | Not studied | Not Studied | 7%
(Su, et al., 2015) | 65% | Not studied | Not studied | Not Studied | 5%

Table C-52 Study Length of Stay Information, Third-Generation Cephalosporin-Resistant P. aeruginosa

Reference | Resistant Strain Sample Size | Susceptible Strain Sample Size | Resistant Strain LOS (Days) | Susceptible Strain LOS (Days) | Excess LOS (Days) | p-value
(Dantas, et al., 2014) | 66 | 44 | 48.5 | 40.5 | 8 | 0.73
(Joo, et al., 2011) | 74 | 128 | 23 | 15 | 8 | 0.023
(Picot-Guéraud, et al., 2015) | 28 | 200 | Not Studied | Not Studied | Not Studied | Not Studied

Table C-53 General Study Information, MDR P. aeruginosa

Reference | Study Design | Enrollment Period | Country | Resistance Reference | Setting | Infection Site | Overall Score
(Borgatta, et al., 2017) | Retrospective study | 1/2010 - 4/2015 | Spain | EUCAST | Multi (4 ICUs) | Pneumonia (HAP/VAP) | 10.0
(Cillóniz, et al., 2016) | Prospective observational study | 1/1999 - 12/2014 | Spain | EUCAST | Single | Pneumonia CAP | 10.0
(Dantas, et al., 2014) | Retrospective study | 5/2009 - 8/2011 | Brazil | CLSI | Single (530-tertiary-care university hospital) | BSI; respiratory tract; UTI | 4.5
(Lu, et al., 2012) | Prospective, observational, and comparative study | 1/2006 - 12/2010 | France | Not Reported | Single (26-bed multidisciplinary ICU) | Pneumonia VAP | 13.0
(Micek, et al., 2015) | Retrospective cohort study | Not Reported | U.S., France, Germany, Italy, Spain | CLSI and EUCAST | Multi (12 hospitals) | Pneumonia nosocomial | 14.0
(Morata, et al., 2012) | Prospective study | 1/2000 - 12/2008 | Spain | CLSI | Single (850-bed university center) | BSI; respiratory | 10.5
(Peña, et al., 2013) | Retrospective study | 1/2006 - 12/2011 | Spain | CLSI | Single (tertiary-care university hospital) | VAP | 10.0
(Peng, et al., 2014) | Case-control surveillance study | 7/2008-12/2012 | China | CLSI | Multi (5 randomly selected tertiary care hospitals) | Any infection | 7.0
(Tam, et al., 2010) | Retrospective cohort study | 1/2005-12/2008 | US | Not Reported | Single (900-bed acute-care teaching hospital) | BSI | 18.0
(Trecarichi, et al., 2011) | Prospective study | 1/2009-9/2010 | Italy | Not Reported | Multi (9 tertiary care centers or university hospitals) | BSI | 8.0
(Tumbarello, et al., 2011) | Retrospective (case-control & cohort study) | 1/2006-12/2007 | Italy | CLSI | Multi (2 hospitals-1600-bed and 1500-bed) | BSI; UTI | 12.0
(Tumbarello, et al., 2020) | Retrospective case-case-control study | 1/2016-12/2017 | Italy | EUCAST | Multi-center (2 hospitals) | UTI | 15.0
(Zhang, et al., 2020) | Retrospective multicenter study | 2012-2019 | China | CLSI | Multi (5 hospitals) | Lung; UTI; BSI | 5.3
(Zhao, et al., 2020) | Retrospective study | 1/2014-12/2019 | China | CLSI | Single-center (767-bed blood diseases hospital) | BSI | 5.0

Table C-54 Study Mortality Information, MDR P. aeruginosa

Reference | Mortality for Resistant Strain | Mortality for Susceptible Strain | Excess Mortality | p-value | Standard Error in Resistant-Strain Mortality
(Borgatta, et al., 2017) | 68% | Not Studied | Not Studied | Not Studied | 8%
(Cillóniz, et al., 2016) | 23% | 17% | 5% | 0.6 | 9%
(Dantas, et al., 2014) | 42% | 41% | 1% | 0.92 | 7%
(Dantas, et al., 2014) | 59% | Not Studied | Not Studied | 19.00% | 12%
(Dantas, et al., 2014) | 40% | Not Studied | Not Studied | 1 | 22%
(Lu, et al., 2012) | 16% | 23% | -7% | 0.357 | 6%
(Micek, et al., 2015) | 45% | 32% | 13% | 0.001 | 3%
(Morata, et al., 2012) | 32% | 17% | 15% | <0.0001 | 4%
(Morata, et al., 2012) | 64% | 44% | 20% | Not Reported | 10%
(Morata, et al., 2012) | 5% | 8% | -3% | Not Reported | 5%
(Peña, et al., 2013) | 50% | 55% | -5% | 0.33 | 6%
(Peng, et al., 2014) | 26% | 13% | 14% | <0.01 | 3%
(Tam, et al., 2010) | 40% | 12% | 28% | 0.003 | 10%
(Trecarichi, et al., 2011) | 41% | 9% | 32% | 0.06 | 9%
(Tumbarello, et al., 2011) | 50% | 24% | 26% | 0.006 | 8%
(Tumbarello, et al., 2020) | 9% | 12% | -3% | 0.49 | 4%
(Zhang, et al., 2020) | 71% | Not Studied | Not Studied | 0.042 | 7%
(Zhang, et al., 2020) | 50% | Not Studied | Not Studied | <0.001 | 6%
(Zhang, et al., 2020) | 0% | Not Studied | Not Studied | 0.066 | Unknown
(Zhao, et al., 2020) | 29% | 5% | 23% | <0.001 | 7%

Table C-55 Study Length of Stay Information, MDR P. aeruginosa

Reference | Resistant Strain Sample Size | Susceptible Strain Sample Size | Resistant Strain LOS (Days) | Susceptible Strain LOS (Days) | Excess LOS (Days) | p-value
(Borgatta, et al., 2017) | 21 | Not Studied | 25 | Not Studied | Not Studied | 0.42
(Cillóniz, et al., 2016) | 22 | 46 | 14 | 11 | 3 | 0.046
(Dantas, et al., 2014) | 57 | 63 | 59 | 62 | -3 | 0.41
(Lu, et al., 2012) | 43 | 122 | 54 | 25 | Not Studied | <0.001
(Micek, et al., 2015) | 226 | 514 | 27 | 25 | Not Studied | 0.09
(Morata, et al., 2012) | 127 | 582 | 31.83 | 16.38 | Not Studied | <0.0001
(Peng, et al., 2014) | 188 | 160 | 39 | 24 | 15 | <0.01
(Tam, et al., 2010) | 25 | 84 | 26.4 | 16.5 | 9.9 | 0.12
(Tumbarello, et al., 2011) | 40 | 66 | 27 | 17 | 10 | 0.01
(Tumbarello, et al., 2020) | 65 | 177 | 48 | 22 | 26 | <0.001
(Zhang, et al., 2020) | 38 | 225 | 27 | 26 | 1 | 0.44

Table C-56 General Study Information, Carbapenem-Resistant E. aerogenes/E. cloacae

Reference | Study Design | Enrollment Period | Country | Resistance Reference | Setting | Infection Site | Overall Score
(Pang, et al., 2018) | Retrospective study | 1/2010-12/2016 | China | CLSI | Multi (3 large comprehensive tertiary hospitals) | Any infection; ventilator-associated bacterial pneumonia; BSI; complicated UTI / acute pyelonephritis; hospital-acquired bacterial pneumonia; superficial wound infection; biliary tract infection; deep wound infection; sterile body fluids infection | 5.3
(Tuon, et al., 2017) | Retrospective cross-sectional study | 1/2010-8/2014 | Brazil | CLSI | Multi | Ventilator-associated pneumonia | 6.5
(Vargas-Alzate, et al., 2018) | Cohort study | 10/2014-9/2015 | Columbia | CLSI | Single (754-bed university hospital) | Pneumonia, BSI, SSI and intra-abdominal | 8.0
(Zhao, et al., 2021) | Retrospective observational study | 1/2003-12/2017 | Scotland | Not Reported | Multi | Any infection | 14.0

Table C-57 Study Mortality Information, Carbapenem-Resistant E. aerogenes/E. cloacae

Reference | Mortality for Resistant Strain | Mortality for Susceptible Strain | Excess Mortality | p-value | Standard Error in Resistant-Strain Mortality
(Pang, et al., 2018) | 23% | Not Studied | Not Studied | Not Studied | 4%
(Pang, et al., 2018) | 32% | Not Studied | Not Studied | Not Studied | 8%
(Pang, et al., 2018) | 45% | Not Studied | Not Studied | Not Studied | 11%
(Pang, et al., 2018) | 6% | Not Studied | Not Studied | Not Studied | 5%
(Pang, et al., 2018) | 25% | Not Studied | Not Studied | Not Studied | 11%
(Pang, et al., 2018) | 6% | Not Studied | Not Studied | Not Studied | 6%
(Pang, et al., 2018) | 0% | Not Studied | Not Studied | Not Studied | Unknown
(Pang, et al., 2018) | 14% | Not Studied | Not Studied | Not Studied | 13%
(Pang, et al., 2018) | 20% | Not Studied | Not Studied | Not Studied | 18%
(Tuon, et al., 2017) | 57% | Not Studied | Not Studied | Not Studied | 5%
(Vargas-Alzate, et al., 2018) | 23% | 13% | 10% | 0.12 | 6%
(Zhao, et al., 2021) | 15% | Not Studied | Not Studied | Not Studied | 3%

Table C-58 Study Length of Stay Information, Carbapenem-Resistant E. aerogenes/E. cloacae

Reference | Resistant Strain Sample Size | Susceptible Strain Sample Size | Resistant Strain LOS (Days) | Susceptible Strain LOS (Days) | Excess LOS (Days) | p-value
(Pang, et al., 2018) | 124 | Not Studied | 11.3 | Not Studied | Not Studied | Not Studied
(Pang, et al., 2018) | 31 | Not Studied | 15.8 | Not Studied | Not Studied | Not Studied
(Pang, et al., 2018) | 22 | Not Studied | 14.6 | Not Studied | Not Studied | Not Studied
(Pang, et al., 2018) | 18 | Not Studied | 6.7 | Not Studied | Not Studied | Not Studied
(Pang, et al., 2018) | 16 | Not Studied | 10.5 | Not Studied | Not Studied | Not Studied
(Pang, et al., 2018) | 16 | Not Studied | 9.3 | Not Studied | Not Studied | Not Studied
(Pang, et al., 2018) | 9 | Not Studied | 7.6 | Not Studied | Not Studied | Not Studied
(Pang, et al., 2018) | 7 | Not Studied | 8.3 | Not Studied | Not Studied | Not Studied
(Pang, et al., 2018) | 5 | Not Studied | 10.4 | Not Studied | Not Studied | Not Studied
(Tuon, et al., 2017) | 112 | Not Studied | 31 | Not Studied | Not Studied | <.001
(Vargas-Alzate, et al., 2018) | 48 | 170 | 15 | 11 | 4 | 0.016
(Zhao, et al., 2021) | 211 | Not Studied | 8 | Not Studied | Not Studied | Not Studied

Table C-59 General Study Information, MDR E. aerogenes/E. cloacae

Reference | Study Design | Enrollment Period | Country | Resistance Reference | Setting | Infection Site | Overall Score
(Zhong, et al., 2012) | Retrospective cohort study | 1/2007-4/2010 | China | CLSI | Single (1586-bed tertiary-care institute specializing in organ transplantation) | Any infection | 6.0

Table C-60 Study Mortality Information, MDR E. aerogenes/E. cloacae

Reference | Mortality for Resistant Strain | Mortality for Susceptible Strain | Excess Mortality | p-value | Standard Error in Resistant-Strain Mortality
(Zhong, et al., 2012) | 38% | 24% | 14% | 0.292 | 8%

39 13 European Countries include: Austria, Belgium, Croatia, England, Germany, Greece, Ireland, Italy, Latvian, Malta, Romania, Scotland, Slovenia