# B APPENDIX PRISMA DIAGRAMS

Acinetobacter baumannii - Carbapenems

*May include studies reviewed for a different pathogen-drug combination and deemed relevant or studies from a supplementary Google search.

**No data was extracted from systematic review, but it was used to identify other studies to include.

Acinetobacter baumannii – Resistant to all three classes

Escherichia coli - Carbapenems

*May include studies reviewed for a different pathogen-drug combination and deemed relevant or studies from a supplementary Google search.

Escherichia coli – Fluoroquinolones

Escherichia coli – 3^rd^ Generation Cephalosporins

Escherichia coli - Resistant to all three classes

Klebsiella pneumonia – Fluoroquinolones

**No data was extracted from systematic review, but it was used to identify other studies to include.

Klebsiella pneumoniae – 3^rd^ Generation Cephalosporins

*May include studies reviewed for a different pathogen-drug combination and deemed relevant or studies from a supplementary Google search.

**No data was extracted from systematic review, but it was used to identify other studies to include.

Klebsiella pneumoniae – Resistant to all three classes

Pseudomonas aeruginosa – Carbapenem

*May include studies reviewed for a different pathogen-drug combination and deemed relevant or studies from a supplementary Google search.

**No data were extracted from systematic review, but it was used to identify other studies to include.

Pseudomonas aeruginosa - Ceftazidime

Pseudomonas aeruginosa – Resistant to all three classes

**No data was extracted from systematic review, but it was used to identify other studies to include

Enterobacter aerogenes/cloacae – Carbapenems

Enterobacter aerogenes/ cloacae – Resistant to all three classes