# A APPENDIX AMR SURVEILLANCE SYSTEMS

## A.1 U.S. SURVEILLANCE

In the U.S., most antimicrobial resistance tracking is managed by the Centers for Disease Control and Prevention (CDC). CDC manages a network of laboratories, the AR lab network, in 50 states and Puerto Rico that uses modern technology to detect antimicrobial resistance and prevent its spread (CDC, 2020).

CDC’s National Healthcare Safety Network (NHSN) “is the nation’s most widely used healthcare-associated infection tracking system,” serving about 25,000 medical facilities (CDC, 2021). NHSN includes data on antibiotic resistance, outpatient antibiotic use, hospital antibiotic stewardship, healthcare-associated infections, and data from public health laboratories. CDC’s Antibiotic Resistance & Patient Safety Portal currently provides National Healthcare Safety Network antimicrobial resistance data from 2011 to 2020 and healthcare-associated infection data from 2015 to 2021. Data are gathered from individual facilities so they can be used to track these metrics at different levels (e.g., facility-, state-, or national-level). The NHSN also tracks prescriptions for individual drugs to assess trends in prescription levels. Antibiotic resistance and healthcare-associated infection data also include hospital type and associated event (e.g., SSIs, catheter-associated UTIs, and central line-associated BSIs). The hospital antibiotic stewardship data provide information on inpatient antibiotic stewardship in acute care hospitals from 2014 through 2019, tracking individual elements of the programs (CDC, n.d.).

Additional surveillance systems include CDC’s Emerging Infections Program, which includes components focused on identifying, understanding, and responding to emerging infections, including monitoring for healthcare-associated infections (CDC, 2022a). Information on all tuberculosis cases, including drug resistance, in the U.S. is monitored through CDC’s National Tuberculosis Surveillance System (Centers for Disease Control and Prevention, 2022b). Enteric (intestinal) bacteria are tracked through the National Antimicrobial Resistance Monitoring System for Enteric Bacteria, under a coordinated effort by CDC, Department of Agriculture, Food and Drug Administration, and state and local health departments. NARMS monitors AMR among enteric bacteria in humans, meat, and food animals (CDC, 2022c).

## A.2 OTHER SURVEILLANCE

Trends and emerging AMR infections in other countries are relevant to the U.S., as infections can spread rapidly across the globe. Trends in AMR may be driven by local conditions, but monitoring global trends provides clues as to what problems could arise in the U.S. In 2015, the World Health Organization (WHO) launched the Global Antimicrobial Resistance and Use Surveillance System (GLASS). GLASS collaborates with and supports regional AMR surveillance networks including networks in Europe, Latin America, Central Asia, and the Western Pacific. GLASS collects a range of data including surveillance of antimicrobial consumption, detection of emerging AMR infections, and targeted surveys and studies (World Health Organization, 2021). As of 2019, 66 countries reported data to the GLASS – AMR program, including 64,761 institutions and over two million European Antimicrobial Resistance Surveillance Network patients (Pessoa-Silva, 2020).

European antimicrobial resistance is tracked by the (EARS-Net). EARS-Net’s predecessor was established in 1998 and became EARS-Net in 2010 (European Centre for Disease Prevention and Control, 2021). EARS-Net collects data on AMR “based on antimicrobial susceptibility testing (AST) results from invasive (blood or cerebrospinal fluid) isolates of eight bacterial species” of public health importance in Europe, including data from 30 EU and European Economic Area countries (European Centre for Disease Prevention and Control, 2020).

The Central Asian and European Surveillance of Antimicrobial Resistance (CAESAR) is a surveillance network covering all countries in the WHO European region that are not part of EARS-Net (World Health Organization Regional Office for Europe, 2021).

Some global efforts attempt to track AMR worldwide. The SENTRY surveillance system provides global surveillance via a network of medical centers in the U.S., Canada, Latin America, Europe, and Asia-Pacific. ResistanceOpen compiles surveillance data to present information on prevalence of resistance in specific pathogens in a geographic area.