# LIST OF ACRONYMS

ABSSSI: Acute bacterial skin and skin structure infection
AMR: Antimicrobial resistance
ARIMA: Autoregressive integrated moving average
ASPE: HHS Office of the Assistant Secretary for Planning and Evaluation
AST: Antimicrobial susceptibility test
BICU: Burn intensive care unit
BSI: Bloodstream infection
CAESAR: Central Asian and European Surveillance of Antimicrobial Resistance
CAP: Community-acquired pneumonia
CDC: Centers for Disease Control and Prevention
CDF: Cumulative distribution function
CLIA: Clinical Laboratory Improvement Amendment
CLSI: Clinical and Laboratory Standards Institute
CMS: Centers for Medicare and Medicaid Services
COVID: Coronavirus disease
CPI: Consumer Price Index
CPO: Carbapenemase-producing organism
CRAB: Carbapenem-resistant Acinetobacter baumannii
CRE: Carbapenem-resistant Enterobacterales
CRKP: Carbapenem-Resistant Klebsiella pneumoniae
CRPA: Carbapenem-resistant Pseudomonas aeruginosa
CSKP: Carbapenem-susceptible Klebsiella pneumoniae
DTR: Difficult-to-treat
EARS-Net: European Antimicrobial Resistance Surveillance Network
ERG: Eastern Research Group, Inc.
ESBL: Extended spectrum beta-lactamase
EUCAST: European Committee on Antimicrobial Susceptibility Testing
FDA: Food and Drug Administration
FRKP: Fluoroquinolone-resistant Klebsiella pneumoniae
GDP: Gross Domestic Product
GLASS: Global Antimicrobial Resistance and Use Surveillance System
GNI: Gram-negative infection
HAI: Healthcare-acquired infection
HAP: Healthcare-acquired pneumonia
HHS: U.S. Department of Health and Human Services
ICU: Intensive care unit
IDSA: Infectious Diseases Society of America
LOS: Length of stay
LRTI: Lower respiratory tract infection
MDR: Multi-drug resistant
MIC: Minimum inhibitory concentration
MRSA: Methicillin-resistant Staphylococcus aureus
NARMS: National Antimicrobial Resistance Monitoring System
NHS: U.K. National Health Service
NHSN: CDC National Healthcare Safety Network
PDR: Pan-resistant infection
PNE: Pneumonia
PPI: Producer-based index
PPL: Priority pathogen list
SSI: Surgical site infection
UTI: Urinary tract infection
VAP: Ventilator-associated pneumonia
WHO: World Health Organization
XDR: Extensively drug-resistant