# NEXT STEPS FOR RESEARCHERS

This new and innovative dataset is poised to advance knowledge about children and families engaged with child welfare and Medicaid systems. This brief aims to spur researchers to begin using these data. The scope of research questions that can be addressed with these data extend beyond what is described in this brief. ASPE is committed to supporting efforts to link data systems to improve the lives of children and families, and aims for this project and the research stemming from it to inspire states and jurisdictions to build similar data infrastructures that align with these goals. For more information about the work ASPE is doing to further assist states with linking child welfare and Medicaid data, please read more about the Child Welfare and Health Infrastructure for Linking and Data Analysis of Resources, Effectiveness, and Needs (CHILDREN) Initiative (https://aspe.hhs.gov/reports/children-initiative-update).

Researchers interested in conducting research using data developed from the CCOULD project can request access to the data directly from NDACAN (https://www.ndacan.acf.hhs.gov/datasets/request-restricted-data.cfm). Access to the data is free of charge, but requires compliance with NDACAN’s standards for data security and approval from an Institutional Review Board (IRB). ASPE plans to support researchers conducting important research at the intersection of child welfare and Medicaid using the CCOULD dataset through a research consortium. More information about the call for proposals under the research consortium can be found here (https://www.irp.wisc.edu/irp-extramural-large-grants-2024-2026-call-for-applications/).