# RESEARCH TOPICS USING CCOULD

This section outlines potential research topic areas and research questions that could be examined using the dataset. These research questions are intended to help researchers get oriented to the data, and do not reflect the full range of questions that could be addressed. Once working with the actual data, researchers will need to refine their specific research questions based on the specific strengths and limitations of the variables and subpopulations of interest. The table below describes topical areas for research, brief insight into the types of variables available in the data that may be useful, as well as potential limitations.

Research Topics | CCOULD variables and source:; 1 = Medicaid claims; 2 = Child Welfare data
Prevalence of substance use disorders among children and caregivers engaged in child welfare systems; How do claims-based indicators of substance use disorders (SUD) in Medicaid data (i.e., diagnosis codes) compare with indicators of SUD in the child welfare data?; Is one system more likely to identify SUD, and make connections to services?; Among people covered by Medicaid, how does the prevalence of SUD compare across children and caregivers based on child welfare system engagement?; Are certain types of SUD (e.g., opioid, alcohol) more commonly diagnosed among Medicaid recipients with child welfare involvement compared to those without?; What percentage of children in the foster care system have a parent with a SUD diagnosis on Medicaid claims and/or child welfare (CW) data?; How frequently are children with identified fetal alcohol spectrum disorders (FASD) in the child welfare system? How do rates of FASD diagnoses compare among non-child welfare engaged children?; How do child welfare outcomes differ for children with identified FSAD compared to those without?; What are the demographic characteristics of parents with alcohol use disorder (AUD) in the sample?; How does access to treatment for parents with AUD differ for those with children engaged in child welfare systems compared to those without?; How do prevalence rates of SUDs among child welfare engaged children and caregivers differ by demographic characteristics?; Considerations in the data:; - Reliance on accuracy of International Classification of Disease (ICD) codes; - Requires cross-referencing of ICD, Healthcare Common Procedure Coding (HCPC) & National Drug Codes (NDCs); - < 3% of cases include Title IV-E SUD-related services; - Child welfare reports include data on caregiver substance use in < 25% of cases (~400,000 records), and does not require a SUD diagnosis; - Requires use of all Medicaid data files to identify possible diagnoses; - Race and ethnicity information relies on child welfare records, and there is high percentage of missing data for child ethnicity | · SUD diagnosis codes (1); · SUD-related services provided by CW (under Title IV-E) (2); · Healthcare Common Procedure Coding (HCPC) and revenue codes to identify SUD treatment (1); · National Drug Codes (NDCs) for medications to treat SUD (1); · ID variable to link parents/caregivers in Medicaid to children in the CW data (1, 2)· Caseworker determinations of the role of alcohol and drugs (2); · Demographic characteristics of parents/caregivers (e.g., age, race, disability status, rural/urban) [1, 2]; · Length of time in foster care, maltreatment incidences, and measures of re-entry (2)
Relationship between SUD or mental health conditions and child welfare engagement and outcomes; How do child welfare outcomes for children with parents with SUDs (e.g., out-of-home removal rates, reunification rates, length of time in out-of-home care) compare to those without identified SUDs? How do these outcomes differ by child demographic characteristics?; How do child welfare outcomes differ among children whose parents have different types of SUDs (e.g., Opioid use disorder, alcohol use disorder, etc.)?; How frequently are parents and caregivers receiving SUD treatment involved in the child welfare and/or Medicaid systems?; What type of SUD treatment are parents and caregivers receiving?; To what extent are postpartum depression or other mental health conditions associated with child welfare involvement, care experiences, and outcomes?; How do child welfare outcomes differ among children of caregivers with mental health diagnoses compared to those who do not?; How do child welfare outcomes differ for children whose caregivers are receiving mental health treatment compared to children of caregivers who are not?; How does receipt of mental health treatment for mental health conditions differ by caregiver demographics including age, race, and gender?; How does psychotropic medication usage differ among child welfare engaged children and adults compared to those without child welfare engagement?; Considerations in the data:; - Reliance on accuracy of ICD codes; - Requires cross-referencing of ICD, Healthcare Common Procedure Coding (HCPC) & National Drug Codes (NDCs); - Certain diagnostic codes (e.g., Fetal Alcohol Syndrome) appear more commonly in secondary or tertiary diagnoses, and are identified alongside other primary diagnoses; - < 3% of cases include Title IV-E SUD-related services; - Requires use of all Medicaid data files to identify possible diagnoses; - Child welfare reports include data on caregiver substance use in < 25% of cases (~400,000 records); - Child placement data available for ~95,000 children; - Race and ethnicity information relies on child welfare records, and there is high percentage of missing data for child ethnicity | · HCPC and revenue codes to identify SUD treatment (1); · SUD treatment codes (2); · NDCs for medications to treat SUD (1); · Clinical characteristics (e.g., mental health diagnosis, hospitalization or ED visit for SUD or overdose) [1]; · ID variable to link parents/caregivers in Medicaid to children in the CW data (1, 2); · SUD diagnosis codes (1); · Length of time in foster care, maltreatment incidences, and measures of re-entry (2); · Mental health-related services provided by CW (under Title IV-E) (2)
Composition of substance use disorder treatment recipients; What demographic characteristics, clinical characteristics, and medical care utilization patterns are associated with parents/caregivers receiving Medicaid-funded SUD treatment?; What demographic characteristics are associated with parents/caregivers receiving Title IV-E funded SUD treatment?; Considerations in the data:; - Reliance on accuracy of ICD codes; - Requires cross-referencing of ICD, Healthcare Common Procedure Coding (HCPC) & National Drug Codes (NDCs); - Requires use of all Medicaid data files to identify possible diagnoses, and use of services & medications; - < 3% of cases include Title IV-E SUD-related services; - Demographic data relies on child welfare records for matched children and caregivers, and there is high percentage of missing data for child ethnicity; - Demographic data for Medicaid comparison datasets is collected less systematically | · Demographic characteristics of parents/caregivers (e.g., age, race, disability status, rural/urban) [1, 2]; · Clinical characteristics (e.g., mental health diagnosis, hospitalization or ED visit for SUD or overdose) [1]; · Medical care utilization patterns (e.g., receipt of primary care) [1]; · HCPC and revenue codes to identify SUD treatment (1); · SUD-related services provided by CW (under Title IV-E) (2); · NDCs for medications to treat SUD (1)
Impact of SUD treatment on child welfare outcomes; How does receipt of SUD treatment by parents/caregivers with children involved with child welfare systems relate to child welfare outcomes, such as length of time in foster care, repeat maltreatment incidences, and re-entry into foster care?; How does having a parent receiving SUD treatment affect out-of-home removal and type of placement decisions?; How does receipt of SUD treatment by parents/caregivers with children engaged in child welfare systems differ by caregiver demographic characteristics?; Considerations in the data:; - Reliance on accuracy of ICD codes; - Requires cross-referencing of ICD, Healthcare Common Procedure Coding (HCPC) & National Drug Codes (NDCs); - < 3% of cases include Title IV-E SUD-related services; - Requires use of all Medicaid data files to identify possible diagnoses; - Requires accounting for multiple foster care incidences per child; - Child welfare reports include data on caregiver substance use in < 25% of cases (~400,000 records); - Child placement data available for ~95,000 children; - Demographic data relies on child welfare records for matched children and caregivers, and there is high percentage of missing data for child ethnicity | · HCPC and revenue codes to identify SUD treatment (1); · SUD-related services provided by CW (under Title IV-E) (2); · NDCs for medications to treat SUD (1); · Length of time in foster care, maltreatment incidences, and measures of re-entry (2); · Demographic characteristics of parents/caregivers (e.g., age, race, disability status, rural/urban) [1, 2]
Relationship between services provided through Title IV-E prevention services (e.g., mental health, substance abuse, and in-home parent skills) and child and caregiver child welfare and health outcomes; Which Title IV-E prevention services are used most often among child welfare involved families?; How does use of Title IV-E prevention services differ among caregivers of various demographic groups?; What is the relationship between receipt of Title IV-E prevention services and caregiver health outcomes (e.g., increase in primary care visits, indicators of improved health, etc.); Considerations in the data:; - Requires use of all Medicaid files for cross-referencing of Healthcare Common Procedure Coding (HCPC) & National Drug Codes (NDCs); - Low percentage of cases documented as receiving certain Title IV-E prevention services due to timing of data collection; - Other child welfare services not funded by Title IV-E (e.g., housing, employment) may also be included in the data, but are not uniformly collected by all states; - Requires accounting for multiple foster care incidences per child; - Child placement data available for ~100,000 children; - Demographic data relies on child welfare records for matched children and caregivers, and there is high percentage of missing data for child ethnicity | · HCPC and revenue codes to identify SUD treatment (1); · NDCs for medications to treat SUD (1); · Title IV-E SUD treatment codes (2); · Length of time in foster care, maltreatment incidences, and measures of re-entry (2); · Demographic characteristics of parents/caregivers (e.g., age, race, disability status, rural/urban) [1, 2]
Use of services for children with substance use related illnesses; What services funded by Medicaid and child welfare systems are used by children born with substance use related illnesses, and their parents?; How are those services related to child health and child welfare outcomes?; What differential diagnoses in children are most commonly associated with parental SUD?; How do substance use related illnesses differ among children of different demographic groups, whether engaged in child welfare systems or not?; Considerations in the data:; - Reliance on accuracy of ICD codes; - Requires cross-referencing of ICD, Healthcare Common Procedure Coding (HCPC) & National Drug Codes (NDCs); - < 3% of cases include Title IV-E SUD-related services; - Requires accounting for multiple foster care incidences per child; - Child placement data available for ~95,000 children; - Demographic data relies on child welfare records for matched children and caregivers, and there is high percentage of missing data for child ethnicity; - Demographic data for Medicaid comparison datasets is collected less systematically | · Diagnosis codes (1); · Length of time in foster care, maltreatment incidences, and measures of re-entry (2); · SUD-related services provided by CW (under Title IV-E) (2); · Length of time in foster care, maltreatment incidences, and measures of re-entry (2); · Demographic characteristics of parents/caregivers (e.g., age, race, disability status, rural/urban) [1, 2]
Medicaid spending for child welfare engaged families; How much does Medicaid spend on SUD treatment among parents with children in the foster care system? How much does Title IV-E spend?; Does spending on parent SUD treatment result in subsequent savings to Medicaid and/or Title IV-E?; Does spending on SUD treatment and/or Title IV-E spending affect foster care spending?; How long do children retain Medicaid enrollment following exits from foster care?; Considerations in the data:; - Reliance on accuracy expenditure & enrollment data; - Longitudinal analyses restricted 5 years of data included | · SUD expenditure data on Medicaid claims (1); · Medicaid enrollment data (1); · SUD expenditure data on CW invoices (2); · Longitudinal data to tracking individual parents and their children over time (2); · Variable to link of parents to children (1, 2)
Health and mental health outcomes for child welfare engaged children; What diagnoses are most common among children engaged in child welfare systems?; How do health outcomes for children engaged in child welfare systems differ by demographic characteristics?; What diagnoses are associated with different forms of maltreatment?; How are the timing of diagnosis and treatment of health problems in children related to timing of child welfare engagement?; How do certain health problems affect child welfare outcomes?; What health diagnoses and healthcare services are received by children in child welfare congregate care settings such as group homes and residential treatment settings?; Does Medicaid data provide insights as to the prevalence or severity of the health issues of children in these care settings?; Considerations in the data:; - Reliance on accuracy of ICD codes; - Requires cross-referencing of ICD, Healthcare Common Procedure Coding (HCPC) & National Drug Codes (NDCs); - Requires use of primary, secondary, and tertiary diagnoses to accurately determine scope of care; - Requires accounting for multiple foster care incidences per child; - Child placement data available for ~95,000 children; - Demographic data relies on child welfare records for matched children and caregivers, and there is high percentage of missing data for child ethnicity | · Diagnosis codes (1); · Medical care utilization patterns (e.g., receipt of primary care) [1]; · Medicaid enrollment data (1); · NDCs, HCPC and revenue (1); · Length of time in foster care, maltreatment incidences, and measures of re-entry (2); · Demographic characteristics of parents/caregivers (e.g., age, race, disability status, rural/urban) [1, 2]