# OVERVIEW OF DATA

The CCOULD dataset consists of 16 data files each containing specific information pertaining to child welfare engagement or Medicaid utilization. Children engaged with child welfare systems in Kentucky and Florida from 2016 to 2021, and their caregivers were included in the dataset. Data files can be merged, and children can be linked to caregivers when present in multiple data files. Instructions for merging data files can be found in the NDACAN documentation. Below are highlights of the available data:

- Information on child welfare system engagement (including allegations and substantiated allegations of child maltreatment) on over 1,000,000 children.
- Information on child welfare services supported in part by federal funds through Title IV-E of the Social Security Act. Note, Title IV-E prevention services data are not yet uniformly collected by states, and some of these data were collected prior to any collection of Title IV-E prevention services data. Certain services may be undercounted.
- Information on foster care episodes for over 95,000 children.
- Information on Medicaid enrollment, diagnoses, inpatient and outpatient claims, and prescription data on over 850,000 children with any child welfare involvement included in the child welfare report data (including allegations and substantiated allegations of child maltreatment), and over 85,000 caregivers with children engaged with child welfare services.
- All Medicaid files have a corresponding randomly selected comparison sample of non -child welfare engaged individuals that can be used for analyses.
- Demographic data (race, ethnicity, and sex)^3^ are available for linked children and caregivers, as well as comparison samples. Note, sexual orientation data are not included.

3 Demographic variables were constructed for the research use dataset. “Race” includes: American Indian or Alaskan Native, Asian, Black or African American, Native Hawaiian or other Pacific Islander, and White. “Ethnicity” includes: Hispanic or Latino (ye s/no). “Sex” includes: male and female, and is labeled “gender” in the dataset.