# INTRODUCTION

A large proportion of children who receive child welfare services are eligible for Medicaid. Linking Medicaid data to child welfare system data can identify opportunities to improve coordination between these two programs and improve the effectiveness and cost-effectiveness of their services, among other objectives. The Child and Caregiver Outcomes Using Linked Data (CCOULD) project provided technical assistance to two states – Kentucky and Florida – in linking their Medicaid administrative claims of children and their caregivers with case-level data from the child welfare system. CCOULD then combined state-specific datasets by mapping them onto a common data model and created a multi-state, deidentified dataset for secondary data analysis by researchers.

CCOULD generated a number of important lessons for how states can link data across child welfare and Medicaid systems. These lessons, as well as other information on the data, are documented in a separate ASPE report, “Linking Child Welfare and Medicaid Data: Lessons Learned from Two States”.^1^ Details on the variables, structure, data quality, and other documentation are available through the National Data Archive on Child Abuse and Neglect (https://www.ndacan.acf.hhs.gov/datasets/pdfs_user_guides/dataset272codebook.pdf) (NDACAN).^2^

The CCOULD project and data demonstrates the importance of research at the nexus of child welfare engagement and Medicaid usage. Linked data on services from child welfare and Medicaid are valuable for understanding a range of questions and topics that address critical challenges faced by families at risk of child welfare system involvement. Such research includes identifying indicators of risk for child abuse and neglect to better target prevention efforts, improving the implementation and effectiveness of interventions designed to treat substance use disorders and other behavioral health challenges, as well as promoting child and family wellbeing.

This brief discusses a range of potential research topics that could be explored using the CCOULD data, with the goal of informing and inspiring researchers to engage critically with this innovative and robust dataset to improve the lives of children and families. Additionally, this brief provides guidance to researchers regarding both the capacity of the data to address essential research questions, as well as limitations of the data to aid researchers in their use of these data.

1 https://aspe.hhs.gov/reports/ccould-lessons-learned-report

2 https://www.ndacan.acf.hhs.gov/datasets/pdfs_user_guides/dataset272codebook.pdf