# References

Ali, M. M., & Ghertner, R. (2022). Is buprenorphine treatment availability associated with decreases in substantiated cases of child maltreatment? Journal of Substance Abuse Treatment, 108780.35430093
Australian Government, Australian Institute of Health and Welfare. (n.d.). SLK-581 guide for use. https://www.aihw.gov.au/getmedia/e1d4d462-8efa-4efa-8831-fa84d6f5d8d9/aodts-nmds-2016-17-SLK-581-guide.pdf.aspx
CDC. (2021). Understanding the opioid overdose epidemic. Centers for Disease Control and Prevention. https://www.cdc.gov/opioids/basics/epidemic.html
Child Welfare Information Gateway. (2020). How the child welfare system works. U.S. Department of Health and Human Services, Administration for Children and Families, Children’s Bureau. https://www.childwelfare.gov/pubs/factsheets/cpswork/
Children’s Bureau (2018). New Legislation – Public Law 115-123, the Family First Prevention Services Act within Division E, Title VII of the Bipartisan Budget Act of 2018. IM-18-02 | The Administration for Children and Families (hhs.gov) (https://www.acf.hhs.gov/cb/policy-guidance/im-18-02)
Children’s Bureau. (2021). Comprehensive Child Welfare Information System (CCWIS): Technical Bulletin #7: CCWIS technical assistance, self-assessment tools, and monitoring reviews. https://www.acf.hhs.gov/sites/default/files/documents/cb/ccwis_tb7_0.pdf
Children’s Bureau. (2022). Comprehensive Child Welfare Information System (CCWIS): Technical bulletin #8: Data exchange standards. https://www.acf.hhs.gov/sites/default/files/documents/cb/ccwis_tb8.pdf
Clary, E., Ribar, C., Weigensberg, E., Radel, L., & Madden, E. (2020). Challenges in providing substance use disorder treatment to child welfare clients in rural communities. U.S. Department of Health and Human Services, Office of the Assistant Secretary for Planning and Evaluation.
Code of Federal Regulations. (n.d.). Part 2 - Confidentiality of substance use disorder patient records. https://www.ecfr.gov/current/title-42/chapter-I/subchapter-A/part-2
Dusetzina, S. B., Tyree, S., Meyer, A. M., Meyer, A., Green, L., Carpenter, W. R. (2014). Linking data for health services research: A framework and instructional guide. (Prepared by the University of North Carolina at Chapel Hill under Contract No. 290-2010-000141.) AHRQ Publication No. 14-EHC033-EF. Rockville, MD: Agency for Healthcare Research and Quality; September 2014. www.effectivehealthcare.ahrq.gov/reports/final.cfm
Gabay, M. (2021). Confidentiality toolkit, OPRE Report 2021-175. Office of Planning, Research, and Evaluation, Administration for Children and Families, U.S. Department of Health and Human Services. Confidentiality Toolkit | The Administration for Children and Families (hhs.gov) (https://www.acf.hhs.gov/opre/report/confidentiality-toolkit)
Ghertner, R., Baldwin, M., Crouse, G., Radel, L., & Waters, A. (2018a). The relationship between substance use indicators and child welfare caseloads. Foster Care, 300, 350,000.
Ghertner, R., Waters, A., Radel, L., & Crouse, G. (2018b). The role of substance use in child welfare caseloads. Children and Youth Services Review, 90, 83–93.
Gladden, R. M., O’Donnell, J., Mattson, C. L., & Seth, P. (2019). Changes in opioid-involved overdose deaths by opioid type and presence of benzodiazepines, cocaine, and methamphetamine—25 states, July–December 2017 to January–June 2018. MMWR. Morbidity and Mortality Weekly Report, 68(34), 737.
Hall, M. T., Wilfong, J., Huebner, R. A., Posze, L., & Willauer, T. (2016). Medication-assisted treatment improves child permanency outcomes for opioid-using families in the child welfare system. Journal of Substance Abuse Treatment, 71, 63–67.27776680
Klaman, S. L., Isaacs, K., Leopold, A., Perpich, J., Hayashi, S., Vender, J., Campopiano, M., & Jones, H. E. (2017). Treating women who are pregnant and parenting for opioid use disorder and the concurrent care of their infants and children: literature review to support national guidance. Journal of Addiction Medicine.
Loch, S. F., Stein, B. D., Ghertner, R., McNeer, E., Dupont, W. D., Smart, R., & Patrick, S. W. (2021). Neonatal opioid withdrawal syndrome is associated with infant foster care entry at the county level: Study examines the association between neonatal opioid withdrawal syndrome and infant foster care. Health Affairs, 40(11), 1776–1783.34644183
Quast, T., Storch, E. A., & Yampolskaya, S. (2018). Opioid prescription rates and child removals: evidence from Florida. Health Affairs, 37(1), 134–139.29309232
Radel, L., Baldwin, M., Crouse, G., Ghertner, R., & Waters, A. (2018a). Medication-assisted treatment for opioid use disorder in the child welfare context: Challenges and opportunities. US Department of Health and Human Services, Office of the Assistant ….
Radel, L., Baldwin, M., Crouse, G., Ghertner, R., & Waters, A. (2018b). Substance use, the opioid epidemic, and the child welfare system: Key findings from a mixed methods study. Washington, DC: Office of the Assistant Secretary for Planning and Evaluation.
SAMHSA. (2016). A collaborative approach to the treatment of pregnant women with opioid use disorders. Rockville, MD: Substance Abuse and Mental Health Services Administration, 1–124.
SAMSHA (2020). Fact Sheet: SAMHSA 42 CFR Part 2 Revised Rule. https://www.samhsa.gov/newsroom/press-announcements/202007131330
Walton, M.T., Schutze, M, Shawndaya, T, Johnston, B. Privacy, Policy, & Permanency: The Family First Prevention Services Act and the use of Administrative Data for Child Welfare Research. (2020). Academy Health.
Weigensberg E, Cornwell D, Leininger L. Superutilization of Child Welfare, Medicaid, and Other Services. Final Report. March, 29, 2018. Superutilization of Child Welfare, Medicaid, and Other Services (mathematica.org) (https://www.mathematica.org/publications/superutilization-of-child-welfare-medicaid-and-other-services)
Wilson, S. J., Price, C. S., Kerns, S. E. U., Dastrup, S. D., & Brown, S. R. (2019). Title IV-E Prevention Services Clearinghouse Handbook of Standards and Procedures, version 1.0, OPRE Report # 2019-56. https://preventionservices.abtsites.com/themes/ffc_theme/pdf/psc_handbook_v1_final_508_compliant.pdf