# Executive Summary

A large proportion of children who receive child welfare services are eligible for Medicaid. Linking Medicaid data to child welfare system data can identify opportunities to improve coordination between these two programs and improve the effectiveness and cost-effectiveness of their services, among other things. To demonstrate how this could be achieved, the Office of the Assistant Secretary for Planning and Evaluation, the Office of Planning and Research within the Administration for Children and Families, and RTI International (RTI) began the Child and Caregiver Outcomes Using Linked Data (CCOULD) project in October 2019.

The goal of the CCOULD project was to provide technical assistance to states in linking the Medicaid administrative claims of children and their caregivers with case-level data from the child welfare system and to combine the state-specific datasets into a multi-state, deidentified dataset for secondary data analysis by researchers. The linked dataset would contain information from both child welfare and Medicaid information systems on case demographics, medical diagnoses, services, outcomes, and other relevant information. The data would facilitate research on the relationships between receipt of child and caregiver Medicaid and child welfare services, health care outcomes, and child welfare outcomes. The passage of the 2018 Family First Prevention Services Act (FFPSA) created new incentives for states to better understand services provided by the child welfare system and/or Medicaid to families at risk of entering or re-entering the child welfare system. This project helped to facilitate these connections and research, by supporting data sharing between agencies and providing the technical expertise to support states in completing the work.

Following robust recruitment efforts by the project team, Kentucky and Florida signed onto the project. Florida created a linked dataset covering 2016 through 2021 that included 80% of children (N = 669,425) who had been in contact with Florida’s child-welfare system. Florida linked 57,512 caregivers of those children to Medicaid records. Of the 669,425 Florida children who were linked to Medicaid, 8.5% also had at least one caregiver linked to Medicaid. Kentucky created a linked data set that covered the period 2016 through 2021 that included 81% of children (N = 216,738) who had been in contact with Kentucky’s child-welfare system. Kentucky linked 46,809 caregivers of those children to Medicaid records. Of the 216,738 Kentucky children linked to Medicaid, 21.3% had a least one caregiver linked to Medicaid.

A de-identified dataset that combines both states’ linked data will be available to researchers through the National Data Archive on Child Abuse and Neglect (NDACAN). This report describes the lessons learned from Kentucky’s and Florida’s experiences linking their child welfare system and Medicaid data.

Lessons learned pertained to (1) state recruitment and short-term and long-term sustainability of the linkage project; (2) data availability, consistency, and quality; (3) state and federal regulations related to data linkage and sharing; and (4) linkage methodologies. Regarding state recruitment and sustainability, it took the project team longer to recruit states than anticipated and more effort than expected to keep states engaged. Future linkage efforts could focus more attention on highlighting the specific operational value to states and their constituents of linking their data. A thorough understanding of states’ data and operational readiness to undertake data linkage is also an important consideration for future efforts.

A lesson learned regarding data availability, consistency, and quality is that child welfare agencies may not have mature data dictionaries and user guides that can be shared. In CCOULD, the lack of documentation resulted in greater time demands on state or local agency personnel with institutional knowledge of the data who had to explain the data elements and infrastructure to the team charged with creating the linked dataset. A second lesson learned regarding data availability was that caregiver information, such as demographics and their relationship to the child, was often missing or incomplete. A third was that states could not readily provide detailed information on the title IV-E prevention services provided. This was due to service and cost data being stored in external service provider systems, child welfare services being paid for via lump sum contracts rather than fee-for-service, and the fact that child welfare services do not currently use standardized codes, as medical services typically do (e.g., current procedure terminology [CPT] codes).

Navigating the state and federal privacy laws and regulations pertaining to the sharing of identifiable child welfare data was challenging. States may benefit from clarifying their child welfare privacy regulations, improving cross-agency data sharing processes, and following federal guidance on navigating confidentiality laws and regulations.

To facilitate the data linkage, the CCOULD project created a common data model that employed the same variables and file structure between the two states, allowing for successful aggregation of linked data from multiple states. The CCOULD project was also able to successfully link most children and caregivers using social security numbers. Linkage of children to parents could be enhanced if Medicaid claims data had a family identifier. Because of a lack of family identifier in Medicaid claims, children and caregivers could only be linked if the caregiver’s identifying information was included in the child welfare data.

The experience in linking data from two states through the CCOULD project provides a solid foundation for future linking efforts. As the value of integrating data across Medicaid and child welfare program becomes more apparent, more and more states may begin to build from this foundation.