# 7 Discussion

Summary of CCOULD Lessons Learned
- Internal data sharing initiatives within state agencies are subject to many legal, procedural, and regulatory provisions, which can slow down intra-agency data sharing.
- Honorarium or site payments may not fully offset participation burden.
- MOUs and DUAs must be site-specific, and negotiations can be time-consuming.
- Real and perceived regulatory and privacy concerns are equally important to address.
- Documentation of state child welfare system variables could be more robust.
- The lack of a family identifier in Medicaid claims and encounters data makes the identification of caregivers challenging.
- State child welfare agencies are enhancing their ability to report on title IV-E prevention services.
- Probabilistic matching may yield additional linkages not captured by deterministic matching.

CCOULD is the first effort focused on producing a research use dataset containing longitudinal, linked child welfare, caregiver, and Medicaid data in two states. This proof-of-concept project has demonstrated the feasibility of supporting states to link child and caregiver records over multiple years and producing a harmonized dataset for researchers. The de-identified linked data from both states will be archived at NDACAN and available to researchers. Archived CCOULD data will allow for a more robust examination of the service receipt and trajectories of children and families involved in child welfare and Medicaid systems in two states. CCOULD data may be particularly well suited for equity analyses, providing the research community with an opportunity to examine equity in the context of factors such as service delivery/receipt and in child and family outcomes.

The sustainability of ongoing child welfare-Medicaid linkage in states participating in CCOULD is not yet known. However, both Florida and Kentucky reported that cross-agency DUAs could facilitate future data sharing and linkage activities. Barriers to sustainability may include state staffing/resource limitations or the absence of a requirement or internal need to analyze integrated data. Answering states’ priority research questions with CCOULD data could support sustainability by illustrating the value of integrated data. Additionally, although the title IV-E prevention program provides funding through title IV-E for certain evidence-based prevention services to eligible children and their families, federal reimbursement requirements dictate the appropriate payer and that services/payments are not duplicative. These requirements may be met more easily if integrated data are available.

CCOULD data are not without their limitations. The research use dataset is limited to two states in the South and Southeast regions of the country and does not contain robust title IV-E prevention data. Toward the end of the CCOULD participation, state child welfare agencies were beginning to incorporate title IV-E prevention services, service dates, and service costs into their data systems. The framework and CDM developed on CCOULD sets the stage for future efforts to recruit additional states and prepare a combined research use dataset that includes title IV-E prevention services data.