# 6 Summary of Challenges, Successes, and Lessons Learned

In this section, we summarize some of the key challenges, successes, and lessons learned from the CCOULD project.

## 6.1 State Participation

As described in Section 1, ASPE and ACF began recruiting states through a webinar in August 2019. The project team continued to recruit states from Fall 2019 through 2020. In August 2020, Kentucky signed a Memorandum of Understanding (MOU) agreeing to participate in the project. In January 2021, Florida signed an MOU confirming its participation in the project.

Challenge: Timeliness of recruiting state participants. It took longer than expected to identify and enroll states willing to partner in the project. There were several reasons candidate states did not participate in CCOULD. Because child welfare and Medicaid agencies are separate organizational entities within state agency systems, it was necessary to conduct outreach and recruitment efforts with each organization prior to scheduling meetings that included both parties. In some candidate states, only one agency—child welfare or Medicaid—was responsive or interested in the project. Some candidate states had already linked their data and therefore did not perceive the project as adding value. Additionally, in Winter 2020, states were focused on addressing the COVID-19 public health emergency, which added to the difficulty of securing state leadership buy-in.

Successes. Despite the delays, two states agreed to participate in the study and successfully completed the data linkage.

Lessons Learned. State capacity/readiness assessments supported the identification of a subset of candidate states and guided recruitment discussions with those states. As previously noted, the project team looked for states that met the following criteria: leadership buy-in, existing infrastructure and capacity for data linkage, and policies that supported data sharing.

States that met the criteria were contacted and invited to learn more about the project through virtual meetings. These meetings allowed the project team to present the goals of the project, learn more about linkage efforts states had engaged in to date, and discuss the logistics and expectations of CCOULD participation.

After states joined the project, it was important to build strong relationships with them and their partners and to provide the technical assistance needed to overcome obstacles around data sharing that emerged as MOUs and DUAs were being reviewed and negotiated.

Future efforts could generate greater state interest in data linkage by pointing to specific information that could be learned from the linked data that would be of clear value to state agencies that oversee child welfare or Medicaid programs. Kentucky noted that the ASPE Research Brief entitled Substance Use, the Opioid Epidemic, and the Child Welfare System: Key Findings from a Mixed Methods Study (Radel et al., 2018b) was important for convincing stakeholders to participate in CCOULD. However, neither Kentucky nor Florida had immediate plans to analyze the data. Federal agencies could canvass state agencies to determine their informational needs for the linked data. Information generated from the CCOULD data set may also be useful as examples to motivate participation. For example, the CCOULD study revealed that at least 80% and 86% of children involved in the child welfare systems in Florida and Kentucky had Medicaid coverage. This datapoint highlights the critical need to coordinate Medicaid services with child welfare services. For example, even parents without Medicaid coverage can receive family therapy under Medicaid if it is determined to be beneficial to the child.

## 6.2 Maintaining Momentum and Sustainability

CCOULD goals were twofold: (1) to provide technical and financial assistance to states during the project period to support the preparation of a linked child welfare and Medicaid dataset and (2) to identify strategies for states to continue to link child welfare and Medicaid data beyond the project period. The project provided each state with a $125,000 honorarium to cover some of the cost of participation. Honorariums were provided directly to Kentucky and to Florida’s research partner (UF).

Challenge 1: Burden on State staff resources. UF indicated that the CCOULD project required 0.71 FTE in labor hours. Kentucky indicated that the CCOULD project took 452 hours or about 0.22 FTE. Securing state staff resources was a challenge for CCOULD. States indicated, at times, that their staff needed to focus on competing priorities, and there was no alternate staff member with the needed analytic and/or information technology expertise.

Challenge 2: Delays in securing DUAs. Securing final DUAs took months (see Figure 5). In both the Kentucky cabinet and Florida’s DCF, changes in leadership necessitated an extension of the DUA negotiation timeline to allow for the new leadership team to become familiar with the CCOULD project. In March 2022 and after the CCOULD DUA was in place, the Kentucky Cabinet streamlined its DUA process and eliminated the involvement of its procurement office. This change will benefit future collaborations.

Successes. Despite delays and participating state staff juggling multiple priorities, the project achieved its objective of partnering with two states, linking child welfare and Medicaid data in each state, and developing a merged, linked dataset that could be accessed by researchers.

Lessons Learned. States completed CCOULD activities outside of their immediate operational needs and mandated activities. It remains to be seen whether states can devote the necessary time and resources state to continue linking their child welfare system and Medicaid data without a sustainable source of funding for such efforts, a regulatory requirement, and/or a pressing internal need. However, we anticipate that the effort required to continue/sustain linkage will be lower post-CCOULD participation, as state agencies have shared data internally and developed infrastructure. Although states that opt to implement the Comprehensive Child Welfare Information System (CCWIS) are required to have a bi-directional data exchange with Medicaid Information Management Systems to support the sharing of data on demographic information, immunizations, prescriptions, and other health services (Children’s Bureau, 2021), CCWIS requirements do not specify the need to link Medicaid and child welfare data for policy analysis, research, or evaluation purposes. As states realize the value of the linked data, and become facile with processes of linking the data, they may be more likely to link and conduct analyses of their data on an ongoing basis to support policy analysis.

Figure 5 Timeline of CCOULD Milestones

## 6.3 Child Welfare Data Availability, Consistency, and Quality

The CDM developed for CCOULD was intended to guide the development of a research use dataset that combined linked child welfare and Medicaid data from two or more states. A set of data quality checks were developed for states to assess and adjust their data as needed before submitting them to RTI for statistical disclosure analysis and harmonization.

Challenge 1: Lack of data documentation. In both states, RTI began the project by asking for data dictionaries and code books; however, Kentucky could not provide complete documentation for its child welfare system data. Florida provided more documentation, but it took several iterations between UF, RTI, and DCF to clarify what each variable in the child welfare file meant and to translate that information into a list of variables that would be contained in the CDM and defined in the RTI-UF DUA.

Successes. Florida’s DCF’s willingness to answer questions about the data as the project progressed ensured that there was a common understanding of the child welfare data structure and variables.

Lessons Learned. To support analysis and evaluation of state child welfare data, states should maintain high-quality data dictionaries. States may be able to leverage the materials that ACF has created such as technical bulletins on data exchange standards to develop data dictionaries (Children’s Bureau, 2022).

Challenge 2: Caregiver information may be missing or incomplete. Information on caregivers was less uniform and robust than information on children. Kentucky and Florida seemed to differ in what information they collected from caregivers (e.g., SSNs), how they described the relationship of the caregiver to the child (e.g., primary/secondary caregiver versus biological parent, foster parent, grandparent), and the extent to which caregiver information was collected or maintained in screened-in maltreatment reports.

Lessons Learned. State child welfare agencies could place greater emphasis on collecting and maintaining detailed information about caregivers, including SSNs. However, this may be contingent on the operational necessity of collecting such information, as federal rules do not require caregivers to provide social security numbers for child welfare services. For example, Kentucky attempts to enroll eligible caregivers in other state programs when they come in contact with the child welfare system (e.g., the Supplemental Nutrition Assistance Program). Therefore, caregivers have an incentive to provide SSNs, and Kentucky staff have an operational reason to collect it. If states are focused on only the data elements required for reporting to NCANDS and AFCARS, PII may not be collected for all caregivers involved in the child welfare system. The availability of caregiver SSNs and demographic information increase the probability of linking caregivers to children, allowing for a more robust examination of child and family outcomes.

Challenge 3: Title IV-E Prevention Services information not available. During CCOULD, both Florida and Kentucky were in the process of incorporating title IV-E prevention services information from external providers into their state data systems. As a result, neither state could provide detailed information on prevention services provided to children and families, or the cost of those services.

Lessons Learned. As these and other states begin to implement the title IV-E prevention program, information about the types of evidence-based prevention services provided, service dates, and service costs will be more readily available. Future data linkage efforts may be in a position to examine the quality and utility of these data.

Challenge 4: Lack of standard codes or definitions in child welfare data systems. Medicaid claims data use standard nomenclature, known as the Healthcare Common Procedure Coding System (https://www.cms.gov/Medicare/Coding/MedHCPCSGenInfo/), for identifying services that are also used by providers to bill for services.

This system was developed and is maintained by the American Medical Association and by CMS. In contrast, ACF does not prescribe standard codes or definitions for the specific child welfare services reported to NCANDS or provided as title IV-E prevention services, though states must report the service category (i.e., mental health, substance use, or parenting support) of each title IV-E prevention service in reporting child-specific data. States may differ in their definitions of child welfare-related interventions, such as substance abuse or mental health services, and information on the duration or intensity of service receipt is often lacking. This may be a natural consequence of Medicaid being both a federal- and state-funded system and of Medicaid data being derived from a fee-for-service payment system. Child welfare providers are paid largely through state contracts or grants that may be reimbursed by federal funds but are not necessarily per-unit of service. As previously noted, the inclusion of title IV-E prevention funded services in state data systems may, over time, increase the standardization and specificity of prevention-related child welfare services.

Lessons Learned. Title IV-E prevention requirements for evidence-based services may advance the quality and completeness of certain services data collected and reported by child welfare agencies. However, title IV-E prevention requirements will not capture all of the services provided by child welfare.

Successes. Using the TMSIS, AFCARS, and NCANDS as a foundation and then refining with the states as needed to reflect their unique data variables and structures, RTI was able to create a common data model that allowed the data from two state Medicaid and child welfare systems to be merged into one dataset. Future projects should build off and enhance the common data model format developed from the CCOULD project.

## 6.4 State and Federal Regulations Related to Sharing Child Welfare Records

Challenge: Navigating complex privacy rules and regulations. CCOULD data were subject to state and Federal privacy and human subject projection regulations. Decisions about data sharing, privacy, and human subjects for CCOULD necessitated the involvement of multiple stakeholders from ASPE, ACF, RTI, Kentucky, and Florida, including staff with technical expertise in child welfare and Medicaid data, legal counsel, HIPAA privacy officers, IRBs, and contracts administrators.

Lessons Learned. Linking efforts can take advantage of existing technical assistance resources. States may benefit from using the Office of Planning and Research’s (OPRE’s) Confidentiality (https://www.acf.hhs.gov/opre/report/confidentiality-toolkit) toolkit (Gabay, 2021), which was released in October 2021. The toolkit focuses on information sharing for individual case planning and decision-making at a program level, rather than research, analysis, and evaluation. Nevertheless, it offers important regulatory context for states to consider when balancing the risks and benefits of data sharing across state Medicaid and child welfare agencies.

Another resource for states is the Children’s Bureau-CMS Toolkit for Data Sharing for Child Welfare Agencies and Medicaid (https://www.acf.hhs.gov/sites/default/files/documents/cb/data-sharing-and-medicaid-toolkit.pdf). This technical guide aims to assist state child welfare and Medicaid agencies in supporting and developing automated, bi-directional data exchanges between their information systems. The guide also includes confidentiality considerations.

States may also benefit from revisiting their laws pertaining to the sharing of child welfare records of research and evaluation, given the evolution in the availability of electronic data, as well as the greater emphasis on preventing child removals.

Collaborating with Kentucky and Florida to navigate privacy and data sharing rules facilitated RTI’s access to the Medicaid claims data which contains claims and diagnosis codes pertaining to substance use disorders.

## 6.5 Linking Child Welfare and Medicaid Data

Once the UF and Kentucky OHDA teams had obtained person-level files for child welfare and Medicaid, the CCOULD project team focused on providing technical assistance and linkage solutions to both states to support the identification of child-caregiver pairs and the preparation of a linked dataset to be submitted to RTI.

Challenge 1: Data quality issues in variables used for linking. As previously noted, the success of deterministic linkage hinges on the quality of the linking variables. It was difficult for states to assess how much missingness existed in proposed linkage variables, as many data systems were not designed to answer questions around the missingness of our proposed linkage variables. Furthermore, maintaining consistent methods and timelines for linking across the two states was challenging. The two states possessed different strengths with regard to linking, and this made it difficult to provide uniform, one-size-fits-all recommendations for conducting the linkage.

Lessons Learned. The heterogenous nature of the two states’ data and administrative systems, in particular the approval of the DUAs and accessing the data, meant that the project timelines needed significant buffer to achieve our goals. The time constraints of the project necessitated linkage solutions that were easily implemented by states, such as the use of the deterministic linkage methods.

Challenge 2: Probabilistic matching can yield more linked data, but the states did not have the time or resources to pursue it. Probabilistic matching may have yielded additional linkages not captured by direct matching using SSN or the long-identifier. However, the project timeline for CCOULD did not allow for an exploratory analysis of probabilistic matching methods.

Lessons Learned. Future efforts could incorporate probabilistic methods. States could benefit from webinars and technical assistance pertaining to probabilistic matching approaches and easier tools to implement probabilistic matching approaches.

Successes. SSNs were more-often available for children than we had anticipated reducing the need to use probabilistic matching. SSNs were available less frequently for caregivers, but they were still available for a significant subset of caregivers. As a result, the project successfully linked thousands and children and caregivers in child welfare to their records in Medicaid.

Based on this two-state case study, SSNs are well-populated and of high quality in child welfare records. We do not know whether this is the case in other states. Kentucky pointed out that its high rate of SSNs may be a result of their decision to structure one of its public assistance divisions with the Department for Community-Based Services, the same department that contains the state’s child welfare division. Staff in the same division can help enroll people in benefits, where SSNs are critical, and investigate allegations of child abuse and neglect. These staff may have established practices that are more diligent about collecting SSNs.

Challenge 3: Lack of family identifiers. Because Medicaid datasets do not usually have a family identifier, children cannot be linked to parents or caregivers using the Medicaid claims files.

Lessons Learned. We linked caregivers in the child welfare file to caregivers in the Medicaid file by first linking caregivers to children in the child welfare data. If there was a family identifier on the Medicaid data, more caregivers could have been found to have Medicaid coverage.

Because they are a unique identifier, SSNs provide the highest-quality linkages between children and caregivers in Medicaid and child welfare systems. However, SSNs are subject to heightened privacy protections under HIPAA and state regulations and are not always available for children and families served by the child welfare system. The project was able to link using SSNs despite these privacy protections by having the states do the linkage, rather than trying to have the external research organization (i.e., RTI) obtain the SSNs and do the data linkage. Future projects may benefit by following this approach.

## 6.6 Data Harmonization

Before submitting the combined dataset to NDACAN, the project team harmonized the data from the two states ensure that all variables were in a uniform format and conformed to the specifications in the Common Data Model. This involved generating and thoroughly reviewing frequency distributions and crosstabs of the variables to ensure that the elements of the dataset, including the variable names, variable labels, and response categories. The review identified only a few inconsistencies which were recoded or re-formatted to be consistent.

Challenge 1: Discrepant variable coding and formats. Harmonization efforts revealed several variables that were coded differently by each state. For example, missing was sometimes coded as “999” rather than “.”; this was not a significant challenge to correct. It required carefully reviewing the frequencies of each state’s submitted data.

Challenge 2: Race/ethnicity information is stored in both the child welfare and Medicaid data systems in Florida and Kentucky. When more than one race was provided for a single person, RTI adjudicated the race variable

Successes: The use of a common data model minimized the discrepancies in data submitted by the two states and resulted in the need for only minor adjustments during harmonization.

## 6.7 Data Archiving

The project team established the following criteria for selecting a data archive:

- Secure storage of large national-level datasets
- Cost to the project and researchers
- Timeline for making the data available to the research community
- Familiarity of the archive to researchers, particularly those who are likely to be interested in child welfare research

We began identifying data archives by searching the internet. After reviewing the search results in the context of our experience and expertise with different data archiving organizations, we narrowed the options to two data archives:

- The National Data Archive on Child Abuse and Neglect (NDACAN) at Cornell University (https://www.ndacan.acf.hhs.gov)
- The Inter-university Consortium for Political and Social Research (ICPSR) at the University of Michigan (https://www.icpsr.umich.edu/icpsrweb/content/datamanagement/index.html)

These two archives are well-known in the research community and have established reputations for the secure storage of large national-level datasets. NDACAN receives its funding through a contract with the U.S. Children’s Bureau and houses about 50 datasets on the topic of child abuse and neglect. ICPSR is funded through grants from several federal agencies and foundations and by annual membership fees paid by universities and research institutions. Members are given free, unlimited access to all datasets. ICPSR houses about 15,000 datasets from all areas of social science research.

Both archives are well-established and are equally qualified to serve as the project’s archive. Ultimately, the project team selected NDACAN as the repository for CCOULD based on accessibility of the data to the research community and the timeline for making the data available. In addition to CCOULD, NDACAN houses three large child welfare datasets familiar to most child welfare researchers: the National Survey of Child and Adolescent Well-Being (NSCAW), the National Child Abuse and Neglect Data System, and the Adoption and Foster Care Analysis and Reporting System.

This was the first time that NDACAN had archived insurance enrollment and encounter data. RTI provided NDACAN information on HIPAA Privacy Rule as well as HIPAA’s guidance regarding methods for de-identification of protected health information. The guidance explains the two methods that can be used to satisfy the Privacy Rule’s de-identification standard: Expert Determination and Safe Harbor. RTI used a combination of expert determination and safe harbor to endure that the data provided to NDACAN was deidentified.

Challenges: Because NDACAN had not previously archived Medicaid claims data, RTI worked closely with NDACAN to address concerns about HIPAA privacy rules and disclosure risk.

Successes: RTI developed clear documentation to explain the approach to de-identifying the claims data and collaborated with NDACAN to determine that the risk of re-disclosure was minimal. Additionally, RTI and NDACAN added a statement to the CCOULD DUA for researchers to indicating that estimates with cells of less than 10 observations should not be