# 5 Case Study: Kentucky

## 5.1 Kentucky’s Participating State Agencies

Several state agencies within the Kentucky Cabinet for Health and Family Services participated in CCOULD, including the Office of Health Data and Analytics (OHDA); Department for Community Based Services (DCBS), which has responsibility for child welfare services; Office of Application Technology Services (OATS); and Department for Medicaid Services (DMS). Researchers in OHDA served as the coordinating center for Kentucky, with responsibility for all data analysis and linkage. The Kentucky Cabinet was the recipient of the CCOULD honorarium. Figure 3 shows the organizational structure of the CCOULD project with the state of Kentucky.

## 5.2 Privacy, Human Subjects Research, and Data Sharing Protections

Kentucky statute 620.050 governing the confidentiality of child welfare maltreatment reports does not include explicit language about data sharing for research or evaluation purposes (see Appendix C for the Statute). The lack of such language made it more difficult to determine the permissibility of sharing these data and necessitated clarifications between the Kentucky Cabinet and the Kentucky Supreme Court. The Kentucky statute allows DCBS to share confidential information about a case with agencies with a “legitimate interest” in receiving the information. It was ultimately determined that the ASPE/ACF federal agency goal of analyzing trends and evaluating programs to improve service offered to DCBS clients is a “legitimate interest” and allowed data to be shared for CCOULD.

Figure 3 Organization of the CCOULD Project in Kentucky

Another area of negotiation prior to the DUA process was the sharing of child and parent/caregiver SSNs internally between the Kentucky Cabinet agencies—specifically between DCBS and the OHDA team linking child welfare and Medicaid records. To ensure that clients are connected to Medicaid and other services they are eligible to receive, DCBS verifies SSNs through the federal Social Security Administration (SSA). Once an SSN is verified, the SSA restricts how it can be used. To allow SSNs to be shared between agencies, no verification indicators from the SSA were passed to OHDA.

In January 2021, the Kentucky Cabinet IRB also determined that CCOULD was exempt human subjects research.

Three DUAs were negotiated and secured before data were linked for CCOULD: (1) a DUA allowing DCBS to share child welfare data with OHDA was signed in November 2021, (2) a DUA allowing DMS to share Medicaid data with OHDA was signed in December 2021, and (3) a DUA allowing OHDA to share linked child welfare and Medicaid data with RTI was signed in January 2022. All PII for individuals in the DMS and DCBS data remained with OHDA and was not shared with RTI. The only PHI that RTI received from OHDA were Medicaid service dates. In March 2022, Kentucky streamlined its DUA process via a Master Data Agreement (MDA) between constituent Cabinet for Health and Family Services agencies, resulting in much faster turnaround for approvals when the DUA needed to be amended to clarify the data elements requested.

## 5.3 Data Availability

Although Kentucky had made significant progress integrating title IV-E prevention services information into its data systems when DUAs were negotiated for CCOULD, these services data were not yet available for linkage.

Prior to the 2018 FFPSA, DCBS partnered with therapeutic foster care organizations and other health and human services agencies to provide services to children and families. As a result, services data were housed in the individual partner systems and not in their data system, Workers Information System (TWIST). Post the state’s implementation of a title IV-E prevention plan, beginning in late 2019, DCBS began adding title IV-E prevention services data to TWIST per ACF requirements.^2^ Variables included type of services received, dates of services, and successful completion of treatment. These data did not include service costs, however, and could not be linked with Medicaid given a 9-month lag in Medicaid data being available for receipt and import. Therefore, the Kentucky child welfare services data available for CCOULD is similar to that provided by Florida.

## 5.4 Data Linkage

Figure 4 describes Kentucky’s processes for investigating and acting upon child welfare calls to their agency. The information from these calls is entered into their TWIST data system. This information was extracted and linked to Medicaid claims data as part of this linkage project.

Table 3 presents the linkage statistics for Kentucky. From 2016 through 2021, the Kentucky child welfare system recorded 278,282 child welfare reports or investigations. These reports represented 268,753 unique children (a child could have more than one report/investigation). The dataset also contained information on 55,033 caregivers.

Kentucky linked 81% (216,738 / 268,753) of the children in the child welfare system to a Medicaid record. Of these 216,738 linked children, 93% (201,095 / 216, 738) were linked via SSN, and 7% (15,643 / 216,738) were linked via LongID. Among the caregivers,85% (45,672 / 46,809) were linked to Medicaid. 98% of caregivers were linked using the SSN. Of the 216,738 Kentucky children linked to Medicaid, 21.3% had a least one caregiver linked to Medicaid.

As in Florida, we assessed the quality of the LongID linkage approach by comparing the agreement between the linkages using the LongID with the linkages using the SSN, assuming that the SSN was the gold standard (i.e., yielded correct linkages). Table 4 displays those statistics. The false negative rates (i.e., the rate for links that should have been made with the LongID but were not) were 9.2% for children and 14.6% for caregivers. The false positive rates (i.e., the rate of links that should not be made with the LongID but were) were 10.5% for children and 10.2% for caregivers. The false negative and positive rates were higher in Kentucky than in Florida.

Figure 4 Kentucky’s Data Generating Process for Child Welfare Cases

CPS = Child Protective Services

Table 3 Child Welfare and Medicaid Linkage Statistics from Kentucky, 2016–2020

Population | Number of Observations | Percentage of Total Children/Caregivers | Percentage by Linked Method
Child Welfare Reports or Investigations occurring from 2016 to 2020 | 278,282
Number of children represented in the child welfare reports or investigations from 2016 to 2020 | 268,753 | 100%
Children linked to Medicaid | 216,738 | 81%
Children linked to Medicaid with SSN | 201,095 | | 93%
Children linked to Medicaid with LongID | 15,643 | | 7%
Unlinked children | 50,103 | 19%
Number of caregivers represented in the child welfare reports or investigations from 2016 to 2020 | 55,033
Caregivers linked to Medicaid | 46,809 | 85%
Caregivers linked to Medicaid with SSN | 45,672 | | 98%
Caregivers linked to Medicaid with LongID | 1,137 | | 2%
Unlinked caregivers | 8,223 | 15%

Table 4 Linkage Testing Among Children and Caregivers with Both SSNs and LongID Information

Population with SSN and LongID Available | Reported Rate, %
Children linked with SSN but not LongID (false negatives) | 9.2
Children linked with LongID but not SSN (false positives) | 10.5
Caregivers linked with SSN but not LongID (false negatives) | 14.6
Caregivers linked with LongID but not SSN (false positives) | 10.2

KY provided the same concerns as UF with regards to linking on SSN alone. However, we again followed the data linkage experts and also, to maintain consistency between the two datasets linked on SSN alone.

2 See https://www.acf.hhs.gov/cb/training-technical-assistance/revised-technical-bulletin; https://www.acf.hhs.gov/cb/training-technical-assistance/technical-bulletin-prevention-program