# 4 Case Study: Florida

## 4.1 Florida’s Participating State Agencies and External Partner

Two Florida state agencies—the Department of Children and Families (DCF; which is responsible for child welfare) and the Agency for Health Care Administration (AHCA; which is responsible for Medicaid)—participated in CCOULD. These agencies have a long-standing relationship of data sharing and analysis with researchers at the University of Florida (UF). Faculty and staff in UF’s Health Outcome and Biomedical Informatics department had extensive prior experience analyzing Florida Medicaid and DCF data for children in foster care. DCF and AHCA opted to continue their collaboration with UF for CCOULD. UF served as the CCOULD coordinating center for Florida, with responsibility for all data analysis and linkage. UF was the recipient of the CCOULD honorarium.

Figure 2 shows the organizational structure of the CCOULD project in Florida.

Figure 2 Organization of the CCOULD project in Florida

## 4.2 Privacy, Human Subjects Research, and Data Sharing Protections

RTI began the project by reviewing the state privacy laws pertaining to the project with the Florida project members. Florida statute 39.202 (see Appendix B) allows for the sharing of child welfare reports for bona fide research purposes, specifically:

(i) Any person authorized by the department who is engaged in the use of such records or information for bona fide research, statistical, or audit purposes. Such individual or entity shall enter into a privacy and security agreement with the department and shall comply with all laws and rules governing the use of such records and information for research and statistical purposes. Information identifying the subjects of such records or information shall be treated as confidential by the researcher and shall not be released in any form.

This provision in the statute supported Florida’s ability to share data for CCOULD.

The UF IRB determined that CCOULD was exempt human subjects research.

UF’s partnership with the Florida state agencies created data-sharing efficiencies for CCOULD. AHCA’s existing contract with UF was amended to add CCOULD as a deliverable. Additionally, because UF was already a designated recipient of data for children in foster care, DCF was able to quickly establish a new agreement with UF to also share data for children with screened-in maltreatment reports. The data use agreement (DUA) between DCF and UF was signed in November 2021.

RTI’s privacy officer negotiated and secured a DUA between RTI and UF that allowed RTI to receive the linked Florida data, conduct quality checks and statistical disclosure analyses on the linked data, and then provide a de-identified linked dataset to a public data archive for access by researchers. Florida use the Federal Demonstration Partnership (“FDP”) DUA templates (https://nam04.safelinks.protection.outlook.com/?url=http%3A%2F%2Fthefdp.org%2Fdefault%2Fcommittees%2Fresearch-compliance%2Fdata-stewardship%2F&data=05%7C01%7Ctmark%40rti.org%7C28c63539003040010a0408da8b895a44%7C2ffc2ede4d4449948082487341fa43fb%7C0%7C0%7C637975720031739651%7CUnknown%7CTWFpbGZsb3d8eyJWIjoiMC4wLjAwMDAiLCJQIjoiV2luMzIiLCJBTiI6Ik1haWwiLCJXVCI6Mn0%3D%7C3000%7C%7C%7C&sdata=bhyTtDWVqyogWYPR%2B%2FRHGFCooHRLmeGgf8dnNzuQvvk%3D&reserved=0)^1^ (One-Way DTUA and the “DTUA Attachment 2 – Limited Data Set). The DUA was signed in July 2021. The DUA included a full list of variables that RTI would receive from UF. The DUA required that all personally identifying information (PII) for individuals in the AHCA and DCF data remained with UF and not be shared with RTI. The only protected health information (PHI) that RTI would receive from UF was Medicaid service dates. RTI would then statistically de-identify the linked dataset before making it available to external researchers.

## 4.3 Data Availability

Linked data for CCOULD were intended to support evaluations of the effectiveness of FFPSA/title IV-E services provided by the child welfare system and/or Medicaid in preventing child welfare involvement or reinvolvement. However, at the time the DUAs were being negotiated for CCOULD, only high-level information on child welfare services provided to children and families (i.e., services variables included in the National Child Abuse and Neglect Data System [NCANDS]) was available in DCF’s Florida Safe Families Network (FSFN), an electronic records and case management system used by DCF to document and track child welfare cases. Detailed information on specific FFPSA-funded child welfare services and interventions, dates of service, and costs was housed separately in 20 local community-based care (CBC) provider agencies in six regions of the state. DCF is currently procuring a vendor to build a new Comprehensive Child Welfare Information System (CCWIS) system, which would consolidate detailed services data from multiple CBC agency data systems into the FSFN. This process is expected to take several years. Additionally, regarding data availability, demographic and identifying data on the parent/caregiver of children reported to DCF were only available for children/families who received in-home or foster care services.

## 4.4 Data Linkage

Florida’s DCF and AHCA passed their respective datasets to UF to conduct the data linkage. RTI worked with all three organizations to ensure a transmission of data to UF for linking, then predominantly worked with UF to create the linked dataset.

Many methods of matching were discussed throughout the project, with particular emphasis on deterministic and probabilistic methods of matching. In November 2021, RTI held a linkage discussion with Florida, Kentucky, ASPE/ACF and CCOULD advisors with expertise in data science and data linkage. The linkage discussion with Florida and Kentucky included how to select high-quality linking variables, methods and decision rules needed for deterministic linkage, merits of deterministic and probabilistic matching, and the methods of probabilistic matching. Because the efficacy of deterministic linkage is a function of the quality of the linkage variables, we emphasized the importance of the selection of variables that have high discriminatory power (e.g., social security number [SSN] has more than 900 million possible correct values, whereas birth month only has 12), low missingness, and low possibility of miscoding.

In prior projects, UF followed a deterministic linkage approach as discussed in Dusetzina (2014), which involved linking using SSN, date of birth, and name. Under the CCOULD Project, UF linked deterministically using only SSN. Experts in data linkage highlighted that using additional variables for deterministic linkage will increase specificity (correctly identifying individuals who should not be linked) at the cost of lowering the sensitivity (correctly identifying individuals across the datasets who should be linked). For example, because names are often spelled differently in different data sets (e.g., William versus Bill), requiring that individuals be linked by SSN, DOB, and name would have resulted in the rejection of more true linkages than linking on SSN alone. UF noted that this approach may have the potential to incorrectly link two individuals assigned the same SSN (e.g., a baby recorded with its mother’s SSN). For this project, however, we followed the advice of the data linkage experts in only linking via SSN.

For children and caregivers without SSNs, UF linked using an ID recommended by RTI consultants, which was termed the LongID. The LongID was modeled after the SLK-581 identifier, which is straightforward to implement and has a low rate of incorrect links (Australian Government, n.d.). The LongID was specified for this use as the concatenation of the first three letters of child or caregiver’s last name + the first two letters of the child or caregiver’s first name + child or caregiver’s date of birth (as DDMMYYYY) + sex (M/F).

Table 1 presents the linkage statistics for Florida. From 2016 through 2021, 1,387,677 child welfare reports or investigations were recorded in the Florida child welfare system. These include reports that were substantiated as well as those that were not determined to be substantiated. These reports represented 837,568 unique children (a child could have more than one report/investigation). Out of 837,568 children, the system had demographic information for 835,758 children (1,385,387 reports/investigations). The dataset also contained demographic information on 84,559 caregivers.

UF linked 80% (669,425 / 835,758) of the children in the child welfare system to a Medicaid record. Of these 669,425 linked children, 70% (470,992 / 669,425) were linked via SSN, and 30% (198,433 / 669,425) were then linked via LongID. The caregiver linkage rate was not as high as the link for the children; 68% (57,152 / 84,559) were linked to Medicaid. Most caregivers were linked using SSN. Almost all children had only one caregiver linked to Medicaid (57,002). Overall, 8.5% of the 699,425 children linked to Medicaid also had a caregiver linked to Medicaid.

Table 1 Child Welfare and Medicaid Linkage Statistics from Florida, 2016–2021

Population | Number of Observations | Percentage of Total Children/Caregivers | Percentage by Linked Method
Child Welfare Reports or Investigations occurring from 2016 to 2020 | 1,385,387
Number of children represented in the child welfare reports or investigations from 2016 to 2020 | 835,758 | 100%
Children linked to Medicaid | 669,425 | 80%
Children linked to Medicaid with SSN | 470,992 | | 70%
Children linked to Medicaid with LongID | 198,433 | | 30%
Unlinked children | 166,333 | 20%
Number of caregivers represented in the child welfare reports of investigations from 2016 to 2020 | 84,559
Caregivers linked to Medicaid | 57,152 | 68%
Caregivers linked to Medicaid with SSN | 55,040 | | 96%
Caregivers linked to Medicaid with LongID | 2,112 | | 4%
Unlinked caregivers | 27,407 | 32%

Note: 50,545 caregivers were associated with children who received foster care and 36,921 caregivers were associated with children who received in-home services. Some of the children who received foster care services may have also received in-home services.

We assessed the quality of the LongID linkage approach by comparing the agreement between the linkages using the LongID to the linkages using the SSN, assuming that the SSN was the gold standard (i.e., yielded correct linkages). Table 2 displays those statistics. The False Negative rates (i.e., the rate for links that should have been made but were not) were 8.9% for children and 7.9% for caregivers. The False Positive rates (i.e., the rate of links that are made that should not be made) were lower; 5.0% for children and 2.9% for caregivers. Because testing indicated that the LongID will result in some incorrect linkages, a variable was added to the research file to indicate which children and caregivers were linked with the LongID and which were linked using SSNs. Researchers concerned about incorrect matches may want to use only those records linked by SSNs.

Table 2 Linkage Testing Among Children and Caregivers with Both SSNs and LongID information

Population with SSN and LongID Available | Reported Rate, %
Children linked with SSN but not LongID (false negatives) | 8.9
Children linked with LongID but not SSN (false positives) | 5.0
Caregivers linked with SSN but not LongID (false negatives) | 7.9
Caregivers linked with LongID but not SSN (false positives) | 2.9

1 See http://thefdp.org/default/committees/research-compliance/data-stewardship/