# 3 Activities Common to Both States

In this section, we discuss activities related to the CCOULD project that were common to both Kentucky and Florida, including the state recruitment, addressing privacy regulations, and developing a common data model.

## 3.1 Recruiting States

While many tribal and local jurisdictions have access to child welfare and Medicaid data, the CCOULD project team determined that the project resources would be most effective in working with state agencies. Tribal and local jurisdictions were considered less likely to have access to the infrastructure and resources needed to conduct the linkage or the volume of data required for robust data analysis. To inform the state selection criteria for the project, ASPE and ACF gathered information from stakeholders with expertise in state data capacity and infrastructure as it related to child welfare and Medicaid data systems. Federal stakeholders consulted included staff from the Division of State Systems at the Children’s Bureau, the Division of State Systems at CMS, and NIDA. Nonfederal experts consulted included the American Public Human Services Association, the National Center for State Courts, Casey Family Programs, and the Arnold Foundation.

In May 2019, ASPE/ACF convened the aforementioned Technical Expert Panel to review draft state selection criteria to inform the recruitment and selection of states to participate in the project. Final selection criteria included the following:

- Interest and support from state executive leadership
- Existing partnerships between Medicaid and child welfare agencies and between Medicaid/child welfare agencies and research partners
- Infrastructure and capacity within Medicaid and child welfare agencies to support data linkage of high-quality data
- Experience linking and sharing data

In August 2019, ASPE/ACF presented an overview of the project’s goals, objectives, and timeline at the National Child Welfare Evaluation Summit and held an informational webinar for interested states and their research partners. The webinar described the project goals, roles and responsibilities of different stakeholders, timeline and level of commitment, and next steps. Before the webinar, ASPE/ACF engaged with Children’s Bureau and CMS partners to inform state child welfare and Medicaid representatives about the webinar. After the webinar, ASPE/ACF and RTI convened conference calls with seven states that expressed interest in the project. Follow-up calls were held with interested candidate states who met the selection criteria.

Kentucky signed onto the project in August 2020, and Florida signed on in January 2021. The project provided each state with an honorarium to offset some costs associated with participating in the project.

## 3.2 Addressing Privacy Rules and Concerns

Access to data from Medicaid and child welfare systems is governed by a range of federal and state statutes, regulations, and other policies. Medicaid data contain protected health information (PHI), and both data systems contain personally identifying information (PII). Federal rules on PHI and medical record privacy are guided by the Federal Health Insurance Accountability and Portability Act (HIPAA) and its implementing rules (45 CFR Part 160 and Subparts A and E of Part 164). Information sharing on substance use treatment are covered by 42 CFR Part 2 (Code of Federal Regulations, n.d.). SAMHSA’s recent guidance on 42-CFR-Part 2 Revised Rule clarifies that “disclosures for research under Part 2 are permitted by a HIPAA-covered entity or business associate to individuals and organizations who are neither HIPAA covered entities, nor subject to the Common Rule (re: Research on Human Subjects)” (SAMHSA, 2020).

Walton et al. (2020) reviewed state laws pertaining to the sharing of child protective services data (i.e., maltreatment investigations and services related information) for research or evaluation. This review revealed that state laws have primarily relied on the language in the Child Abuse Prevention and Treatment Act that established annual reporting of state data through NCANDS to outline the terms of child protective services data sharing for research and evaluation. They identified 29 states that expressly describe disclosure of their child protective services case data to those engaged in research, and 23 states (including Washington, DC, and Puerto Rico) have no such language.

RTI provided support to Florida and Kentucky in identifying federal guidance and legal expertise to interpret these relevant privacy rules, eventually determining that none of the rules impeded data linking as envisioned by CCOULD. More details on state-specific privacy rules are addressed below. In November 2020, RTI’s Institutional Review Board (IRB) determined that the CCOULD project was human subjects research classified as “exempt”, qualifying in the category of a demonstration project supported by a federal agency.

## 3.3 Common Data Model

Common Data Models (CDMs) allow for the systematic analysis of disparate databases by transforming data contained within those databases into a common format (data model) as well as a common representation (terminologies, vocabularies, coding schemes). On the Medicaid side, the CCOULD CDM includes information on Medicaid enrollment, diagnoses, procedures, healthcare services, and Medicaid expenditures. Medicaid file structures and variables were based on the Transformed Medicaid Statistical Information System (https://www.medicaid.gov/medicaid/data-systems/macbis/transformed-medicaid-statistical-information-system-t-msis/index.html) (T-MSIS) analytic file structure and data dictionaries. T-MSIS analytic files are a series of datasets created by CMS from state-submitted Medicaid program data that are optimized for analytics.

On the child welfare side, the CDM includes information on reports of maltreatment, investigations, report dispositions and maltreatment types, foster care entry and exit dates, circumstances associated with a child’s removal, total numbers of removals from home, and placement types. The child welfare service variables were selected and coded, drawing from the variables submitted to the Federal government by state child welfare agencies in the National Child Abuse and Neglect Data System (https://www.acf.hhs.gov/cb/data-research/ncands) (NCANDS) and the Adoption and Foster Care Analysis and Reporting System (https://www.acf.hhs.gov/cb/data-research/adoption-fostercare) (AFCARS). The CDM also contains a series of child- and adult-level flags designed to facilitate use of the dataset by researchers unfamiliar with either Medicaid or child welfare data.

Because Florida and Kentucky were both familiar with T-MSIS, NCANDS, and AFCARS, both states were able to adapt their data to the CDM. The Medicaid administrative claims for Florida and Kentucky matched the CDM structure straightforward. The child welfare data took additional effort because the data were stored in structures that required merging and cross-checking.

The CDM is described in two files: an Excel workbook and programming specifications (see Appendix A). The Excel workbook contains worksheets coinciding with each data file. The worksheets list the variables contained in the data files, the source of the variables, the variable’s character type and length, and the variable label. An introduction sheet includes file structure information and research questions to be answered with the data. The programming specifications provide detailed guidance on variable definition and how to derive each of the Medicaid-specific files in the CDM. The files in the CDM adhere to the structure laid out in Figure 1.

Figure 1 Common Data Model File Structure

Shape Description automatically generated with low confidence