# 2 Background

Public child welfare agencies typically receive and investigate reports of possible child abuse and neglect; provide services to families who may need assistance to safely care for their children; arrange for children to live with relatives or with foster families when they determine the children cannot remain at home; and arrange for reunification with their families of origin or other permanent families or connections for children and youth when they cannot return to their family of origin (Child Welfare Information Gateway, 2020). Medicaid is a joint federal-state insurance program that provides health insurance to lower-income children and families. Many children who receive child welfare services or are in foster care are also eligible for Medicaid. Many parents and caregivers of children placed in foster care may also be eligible for and receive Medicaid. By linking data among children and their caregivers who are served by both systems, agencies, researchers, and other interested groups can identify opportunities to improve service provision, care coordination, and potentially improve child and family outcomes.

A number of contextual factors indicate the need for linking data between child welfare and Medicaid systems. Little is known about how utilization of Medicaid services relates to child welfare-related outcomes, and increasing access to linked data can generate research on this topic. Research has demonstrated that children in foster care utilize more Medicaid serves than comparable children not in foster care (Weigensberg et al., 2018). As child welfare stakeholders across the country are increasingly focused on capitalizing on opportunities to support and serve families to prevent involvement in child welfare systems and subsequent placement in foster care, it is critical to understand how Medicaid-funded services can prevent such involvement.

Relatedly, the federal Family First Prevention Services Act (FFPSA; P.L. 115-123), which was enacted in February 2018, has several provisions to enhance public child welfare agency services for families to help children remain at home, to reduce the unnecessary use of congregate care, and to build the capacity of communities to support children and families (Children’s Bureau, 2018). The law enables states and tribes operating a title IV-E program to use title IV-E funds for prevention services and programs identified by the Title IV-E Prevention Services Clearinghouse as meeting the evidence-based requirements in law, including mental health programs, substance abuse prevention and treatment, and in-home parent skill-based programs. Some aspects of these services may also be funded through Medicaid. In many cases, without linked data it is not possible to know when families are using services funded by these separate sources. Analysis of linked data can help determine how best to coordinate and optimize Medicaid and child welfare funding streams to reach program goals.

Linked data on services from child welfare and Medicaid can help us understand the effectiveness of interventions and improve coordination to address critical challenges faced by families at risk of child welfare system involvement. One such challenge is the ongoing overdose crisis. Parental substance use has long been associated with foster care placement (CDC, 2021; Clary et al., 2020; Ghertner et al., 2018a; Ghertner et al., 2018b; Gladden et al., 2019; Klaman et al., 2017; Quast et al., 2018; Radel et al., 2018a, 2018b; SAMHSA, 2016; Wilson et al., 2019) and increased complexity and severity of child maltreatment cases (Ghertner et al., 2018b). As the overdose crisis has worsened (CDC, 2021; Gladden et al., 2019), more young children have been reported to child welfare services and placed out of home (Quast et al., 2018). This problem is especially pronounced in the field of maternal/fetal medicine, where neonatal opioid withdrawal syndrome has been a signicant reason for placing infants in foster care (Loch et al., 2021). Receipt of substance use disorder services, such as medications and counseling, allows parents to increase their functioning and care for their families (Clary et al., 2020; Klaman et al., 2017; Radel et al., 2018a; SAMHSA, 2016; Wilson et al., 2019). Recent studies have specifically identified favorable associations between providing medications for opioid use disorder and a family’s child welfare outcomes (Ali & Ghertner, 2022; Hall, Wilfong, Huebner, Posze, & Willauer, 2016). By linking Medicaid and child welfare data, policymakers can improve access to and coordination of substance use disorder interventions among families involved in both systems.

In the next sections, we present case studies describing Florida’s and Kentucky’s experiences linking child welfare and Medicaid data, and a summary of the lessons learned across both states.