# 1 Introduction

State or local child welfare systems and Medicaid programs have historically operated as largely separate systems. As child welfare programs focus more on preventing family removals, there is need to coordinate information and operations across child welfare and Medicaid programs. For example, the opioid epidemic had a cascading effect on children, leading to decreased family stability and increased family separations (Ghertner et al., 2018b). Connecting parents identified by the child welfare system as needing substance use treatment with Medicaid-funded treatment may help support parents in caring for their children and prevent separations.

The Child and Caregiver Outcomes Using Linked Data (CCOULD) project aimed to partner with two to four states to create a linked dataset of state Medicaid and child welfare system data that would facilitate research on the relationships between child and caregiver Medicaid coverage and services and child welfare services, health care outcomes, and child welfare outcomes. The project was funded by the Patient-Centered Outcomes Research Trust Fund in the U.S. Department of Health and Human Services (HHS) and guided by a Technical Expert Panel that included representatives from the Administration for Children and Families (ACF), the Office of the Assistant Secretary for Planning and Evaluation (ASPE) the Agency for Healthcare Research and Quality (AHRQ), the Centers for Medicare & Medicaid Services (CMS), the National Institute on Drug Abuse (NIDA), and the Substance Abuse and Mental Health Services Administration (SAMHSA).

The document is intended to provide information to state, tribal, and local child welfare, Medicaid, and behavioral health agencies that are interested in linking their Medicaid and child welfare data. The document may also be of interest to HHS agencies whose mission involves improving outcomes and services delivered to children served by child welfare agencies and the Medicaid program. Research organizations and technical assistance providers that collaborate with local agencies on similar projects or that study the relationship between Medicaid and child welfare may also benefit from the information provided. Finally, children and family advocacy organizations, which have been pressing for greater integration and coordination between child welfare and Medicaid, may value the lessons learned from this project.

The project team collaborated with Kentucky and Florida to link their child welfare and Medicaid data. This document describes the experiences of these two states in successfully linking Medicaid and child welfare data. For each state we describe the following:

- The roles and responsibilities of the agencies and external partners in the project
- The processes used to ensure that the project conformed to all Federal and state regulations pertaining to human subjects research, privacy protections, and data sharing
- The data elements available from Medicaid and child welfare and the quality of the data (e.g., degree of missingness)
- The development of a common data model to ensure that states’ data could be combined into one dataset using common variable definitions and data structures
- The methods used to link Medicaid and child welfare data and the linkage success rates

We conclude the report with a summary of challenges, successes, and lessons learned across both states.

The lessons learned from Kentucky and Florida’s experience linking Medicaid and child welfare data may not completely extend to other states. States differ in their organization, processes, legal and regulatory frameworks, and data structure, which may limit the generalizability of the lessons learned from Kentucky and Florida. Regardless, the success these states had should serve as motivation to other jurisdictions interested in linking data, and insights from the project can inform similar efforts in other places.