# Acknowledgments

We would like to recognize the contributions of Andrew Barclay, Jeannette Betancourt, Kailyn Conner, Benjamin Duncan, Jemirah Holland, Rachel LaCroix, Jiawei Li, Robin Preston, Ramesh Raghavan, Deepa Ranka, Maik Schutze, Angela Taylor, Yanning Wang, Matthew Walton, James Weaver, and Pamela Wright.