# Appendix A Common Data Model

CCOULD Project

## Extraction code and syntax for states

### June 30, 2022

The goal of this document is to provide detailed syntax on variable definitions and how to derive each of the child-welfare- and Medicaid-specific files in the Common Data Model (CDM) for the Child and Caregiver Outcomes Using Linked Data (CCOULD) project for the each of the two states in the CCOULD project. Additional guidance is provided for the child welfare and flags files.

#### Medicaid Data

Medicaid Enrollment File. Additional detail on variable coding can be found on the Medicaid Enrollment tab in the CCOULD_CDM_DRAFT_MO_D_YYYY.xlsx spreadsheet. Here we provide decision rules for how to roll up the requested data elements to a monthly level. The file will use enrollment/eligibility records from 2016 through 2020. Where possible we refer to specific fields as they are indicated in the CDM spreadsheet.

We do not provide decision rules for the following variables: CCOULD_ID, CYEAR, MONTH, SUBMTG_ST. Here are the decision rules for rolling up the remaining variables for the monthly enrollment file:

1. [underlined: MCO (derived from DSS.T_CA_PROV_KEY.ID_MEDICAID):] This variable should indicate if the member was enrolled in a Medicaid managed care organization (MCO) during the month. If they have at least one day of MCO enrollment set this variable to 1; otherwise, set this variable to 0. This variable should not indicate the specific MCO in which the member was enrolled.
2. Eligibility information:
  a. [underlined: CHIP (derived from DSS.T_RE_AID_ELIG_DN.CDE_AID_CATEGORY):] If a member has any days during the month of CHIP enrollment, then set this variable to 1; otherwise, set this variable to 0.
  b. [underlined: FOSTER (derived from DSS.T_RE_AID_ELIG_DN.CDE_AID_CATEGORY):] If a member has any days during the month with a foster care program code, then set this variable to 1; otherwise, set this variable to 0.
  c. [underlined: DUAL (derived from DSS.T_RE_BASE_DN.IND_MEDICARE_A and DSS.T_RE_BASE_DN.IND_MEDICARE_B):] If a member has any days of dual eligibility for Medicare and Medicaid during the month, then set this variable to 1; otherwise, set this variable to 0.
  d. [underlined: DISABLED (derived from DSS_T_CDE_AID3.CDE_ABD):] If a member was eligible for Medicaid due to disability during the month, then set this variable to 1; otherwise, set this variable to 0.
  e. [underlined: RESTRCT_BNFT (derived from DSS_T_CDE_AID3.CDE_ABD):] If a member was only eligible for some Medicaid benefits during the month (e.g., they were only eligible for medical benefits, and were not eligible for pharmacy benefits), then set this variable to 1; otherwise, set this variable to 0.

After rolling the data up to a monthly level, retain one record per member per month (if a member is not enrolled at all during a month, there should be no record for that month), and only retain the variables that are listed in the Common Data Model (see the Medicaid Enrollment tab).

Inpatient (IP) and Other Therapy (OT) Header Files. The first step is to split medical claims into two types. The first type will go into the IP Header File and will include all facility inpatient claims defined as facility claims with a type of bill code = 011x-012x (Inpatient hospital), 018x (Swing bed hospital), 021x-022x (Inpatient skilled nursing), or 028x (Swing bed skilled nursing). All other claims, which will include a mix of facility and professional, will go in the OT Header File. Between the two files, this should encompass all medical claims from 2016 through 2020.

After splitting claims into these two buckets, the second step is to roll up a core set of variables to a “header” level. The purpose of this header file is to provide an easier-to-use file that contains a subset of claim information that researchers will frequently need on one record per unique claim ID. We will also retain the data at a line level to ensure that we do not lose details that may be needed by researchers on a more infrequent basis. Roll up rules are as follows:

1. [underlined: Date variables (ADMT_DT, DSCHRG_DT, SRVC_FROM_DT, and SRVC_THRU_DT: derived from DTE_ADMISSION, DTE_DISCHARGE, DTE_FIRST_SVC, and DTE_LAST_SVC):] If there are more than one start and end date (e.g., admission and discharge date) within the same CLAIM_ID, then retain the earliest start date and the latest end date on the header.
  a. The CDM refers to “Best Date”. By Best Date, we mean to prioritize dates as indicated above: the admission dates and discharge dates should be prioritized on the claim. In the absence of an admission and discharge date, use the service from date and service through date.
  b. When handling date variables for the header record, it may make sense to also derive two new variables:
    i. If DSS.T_CA_ICN.DTE_DISCHARGE occurs before
      DSS.T_CA_ICN.DTE_ADMISSION, set
      DSS.T_CA_ICN.DTE_DISCHARGE equal to DSS.T_CA_ICN. DTE_ADMISSION.
    ii. Then create two new variables:
      1. START_DT = DSS.T_CA_ICN.DTE_ADMISSION if DSS.T_CA_ICN.DTE_ADMISSION ne missing; otherwise, = DSS.T_CA_HDR_DTL.DTE_FIRST_SVC.
      2. END_DT = DSS.T_CA_ICN.DTE_DISCHARGE if DSS.T_CA_ICN.DTE_DISCHARGE ne missing; otherwise, = DSS.T_CA_HDR_DTL.DTE_LAST_SVC.
    The point of these latter two variables is to capture the best service date for the claim, which we assume to be an admission or discharge date where that date exists.
2. [underlined: Diagnosis codes (DX* derived from DSS.T_CA_ICN.CDE_DIAG_*):] For the IP Header File keep up to 12 diagnosis codes at the header level; for the OT Header File keep up to 5 diagnosis codes at the header level. Because there could be claims that have multiple distinct sets of diagnosis codes at the line level, we will keep all diagnosis codes at a line level. If the first (second, third, etc.) diagnosis code differs across lines, then retain the diagnosis code from the line with the earliest start date.
3. [underlined: Procedure codes (PROC* derived from DSS.T_CA_ICN.CDE_PROC_PRIM):] For the IP Header File keep the first 6 procedure codes at the header level, after sorting data on START_DT within CLAIM_ID. We will store all procedure codes at a line level for OT claims.
4. [underlined: Place of Service (POS derived from DSS.T_CA_CLAIM_KEY.CDE_POS):] If there is more than one POS code across lines within the same CLAIM_ID, then assign the POS associated with the line that has the largest AMT_BILLED.
5. [underlined: Billing provider data (BILL_PRVDR_NPI, BILL_PRVDR_TXNMY, BILL_PRVDR_TYP [the] [underlined: latter derived from BILL_PROV_TYPE]):] If there is more than one billing provider across lines within the same CLAIM_ID, then assign the billing provider associated with the earliest START_DT.
6. [underlined: Billed and paid amounts (BILL_AMT derived from AMT_BILLED and MDCD_PMT derived from AMT_PAID):] Sum the amounts from each individual line to provide a header total for the entire claim.
  a. For any of the following: prepaid amount, copayment amount, coinsurance amount, deductible amount, and generic. Please leave blank if not available.
7. [underlined: Taxonomy:] Please map your provider specialty codes to CMS national provider taxonomy codes.
8. [underlined: Type of Service:] Please ensure that your Type of Service variable is consistent with the Medicare Claims Processing Manual (see here for more detail. (https://www.cms.gov/Regulations-and-Guidance/Guidance/Manuals/Downloads/clm104c26pdf.pdf)) If type of service is not available, please ignore this variable.

We would like to keep both acute and non-acute inpatient stays in the inpatient file. We are adding to the CDM an additional flag for acute stays based on the bill type. Set the acute stay flag equal to 1 if the bill type is 011x or 012x, otherwise set to 0.

Inpatient (IP) and Other Therapy (OT) Line Files. Follow the same process to separate claims into IP and OT buckets as with the corresponding header files.

Then rename variables according to the CDM documentation on the Medicaid IP OT Line tab. These files will keep the same structure as the data presented in the Limited Dataset Dictionary.

Pharmacy Claims. Separate out pharmacy claims from other claims.

Then rename variables according to the CDM documentation on the Medicaid Pharmacy Claims tab. This file will keep the same structure as the data presented in the Limited Dataset Dictionary.

#### Child welfare files

Living arrangements. To attach the living arrangements table to a specific report, please select the report that is prior to and closest in time to livarr1_st_dt.

#### Xwalk files

FamID. If a family ID is not present in the child welfare report data, please assign a family ID to every unique caregiver and child pair.

The following strategies are used to assign a rpt_id for child-caregiver pairs For child-caregiver pairs identified from foster care episodes:

- Select the report matching on the removal date shown in the NCANDS file (ch_srvc_foster_cr_dt)
- Select the report with the investigation start date (inv_start_dt) and the investigation completion date in NCANDS (rpt_disposition_dt) covering the removal date. If more than one reports are found, prioritize the one with the investigation start date (inv_start_dt) closet in time to the removal date.
- Select the report with the investigation start date (inv_start_dt) that is prior to and closet in time to the removal date.
- Select the report with the investigation start date (inv_start_dt) that is after and closet in time to the removal date.

For child-caregiver pairs identified from in-home services but not foster care episodes:

- Select the report with the earliest investigation start date (inv_start_dt) for the child.

#### Flags files

Child-Level Flags File. The child-level flags file is meant to provide a set of ready-to-use measures at the child level that can be used as a starting point for a variety of research studies. This file does not contain every measure that a research study may need but focuses on the most likely needed measures. Additional measures can be derived, and tailored to specific research objectives, from the other files included in the Common Data Model (CDM).

Here are the specifications for the derived variables in the child-level flags file:

1. RPT_DT_EARLIEST_ANY: use the child welfare report file and find the earliest RPT_DTs
2. RPT_DT_EARLIEST: use the child welfare report file and find the earliest RPT_DT where RPT_DISPOSITION=1 (Substantiated).
3. RPT_DT_MOST_RECENT = use the child welfare report file and find the latest RPT_DT where RPT_DISPOSITION=1 (Substantiated).
4. MAL_ALLCNT: use the child welfare report file and count the number of unique reports (RPT_ID) where RPT_DISPOSITION=1 (substantiated).
5. MAL_PHYCNT: use the child welfare report file and count the number of unique reports (RPT_ID) where CH_MAL_* = 1 (Physical Abuse) and CH_MAL_*_DISPOSITION = 1 (Substantiated).
  Notes: “*” is a wildcard indicating that any of the CH_MAL_1 through CH_MAL_4 could be used as a criterion for the inclusion of a report in this count.
  If CH_MAL_* = 1 (Physical Abuse), but the associated CH_MAL_*_DISPOSITION ne 1, then do not include the report in this count. For example, if CH_MAL_1 = 1 and CH_MAL_1_DISPOSITION ne 1 but CH_MAL_2_DISPOSITION = 1, then do not include.
6. MAL_NEGCNT: same as above, but CH_MAL_* = 2 (Neglect or Deprivation of Necessities).
7. MAL_MEDNEGCNT: same as above, but CH_MAL_* = 3 (Medical Neglect).
8. MAL_SEXCNT: same as above, but CH_MAL_* = 4 (Sexual Abuse).
9. MAL_PSYCNT: same as above, but CH_MAL_* = 5 (Psychological or Emotional Maltreatment).
10. MAL_SUBEXPINF: set to 1 if the following criteria are met:
  a. The child is an infant: CH_AGE_AT_RPT_DT = 0.
  b. Referred to CPS by a health care provider: RPT_SRC = 2 (medical personnel).
  c. Born with and identified as being affected by substance abuse or withdrawal symptoms: CH_ALC = 1 OR CH_DRG = 1 OR [CH_SRVC_SUD=1 AND (CH_ALC = 1 OR CH_DRG = 1)]
11. FC_PLCMT_EVER: use the child foster care (FC) episode file and set to one if the child (CCOULD_ID) has any records in the child FC episode file.
12. FC_PLCMT_CNT: count the number of episodes for the child observed in the child FC episode file. This will be based on the federal guidelines – number of placements.
13. RPT_SUBABUSE: use the child welfare file and set this variable to 1 if the child (CCOULD_ID) has any report where CH_ALC = 1 or CH_DRG = 1.
14. RPT_INTDISAB: use the child welfare file and set this variable to 1 if the child (CCOULD_ID) has any report where CH_INTDIS = 1.
15. CLM_PHYCONCNT: use the Medicaid IP and OT line files and set this variable equal to 1 if there are any claims for the child (CCOULD_ID) where any of the diagnosis codes DX* = T7412XA.
16. CLM_PHYSUSCNT: same as above, but DX* = T7612XA.
17. CLM_NEGCONCNT: same as above, but DX* = T7402XA.
18. CLM_NEGSUSCNT: same as above, but DX* = T7602XA.
19. CLM_SHKBABY: same as above, but DX* = T744XXA.
20. CLM_NOSCHLDABCONCNT: same as above, but DX* = T7492XA.
21. CLM_NOSCHLDABSUSCNT: same as above, but DX* = T7692XA.
22. ANY_BHDX: use the Medicaid IP and OT Header files and set this variable to 1 if the ch ( ) ild (CCOULD_ID) has any claim with a primary diagnosis code (DX1) = F01-F99.
23. CLM_MHPHYSIO: same as above but set to 1 if (DX1) = F01-F09.
24. CLM_MHANYSUD: same as above but set to 1 if DX1 = F10-F19.
25. CLM_MHALC: same as above but set to 1 if DX1 = F10.
26. CLM_MHOPIOID: same as above but set to 1 if DX1 = F11.
27. CLM_MHCANNAB: same as above but set to 1 if DX1 = F12.
28. CLM_MHSED: same as above but set to 1 if DX1 = F13.
29. CLM_MHCOCAINE: same as above but set to 1 if DX1 = F14.
30. CLM_MHOTHSTIM: same as above but set to 1 if DX1 = F15.
31. CLM_MHHALLU: same as above but set to 1 if DX1 = F16.
32. CLM_MHNICOT: same as above but set to 1 if DX1 = F17.
33. CLM_MHINH: same as above but set to 1 if DX1 = F18.
34. CLM_MHOTHPSYSUB: same as above but set to 1 if DX1 = F19.
35. CLM_MHNONMOODPSYDIS: same as above but set to 1 if DX1 = F20-F29.
36. CLM_MHMOODDIS: same as above but set to 1 if DX1 = F30-F39.
37. CLM_MHNONPSYMETDIS: same as above but set to 1 if DX1 = F40-F49.
38. CLM_MHBEHAVSYN: same as above but set to 1 if DX1 = F50-F59.
39. CLM_MHPERDIS: same as above but set to 1 if DX1 = F60-F69.
40. CLM_MHINTELDISAB: same as above but set to 1 if DX1 = F70-F79.
41. CLM_MHDEVDIS: same as above but set to 1 if DX1 = F80-F89.
42. CLM_MHBEHDISCHILD: same as above but set to 1 if DX1 = F90-F98.
43. CLM_MHUNSPEC: same as above but set to 1 if DX1 = F99.
44. BH_RX_PSYCHOTROPIC: use the Medicaid Pharmacy claims and set this variable to 1 if the child (CCOULD_ID) ever has a pharmacy claim with an NDC code = any of the codes in the “Psychotropic NDCs” value set in the CCOULD_VSD.xlsx spreadsheet.
45. BH_RX_MOUD: use the Medicaid Pharmacy Claims and set this variable to 1 if the child (CCOULD_ID) ever has a pharmacy claim with an NDC code = any of the codes in the “MOUD NDCs” value set in the CCOULD_VSD.xlsx spreadsheet.
46. BH_RX_MAUD: use the Medicaid Pharmacy Claims and set this variable to 1 if the child (CCOULD_ID) ever has a pharmacy claim with an NDC code = any of the codes in the “MAUD NDCs” value set in the CCOULD_VSD.xlsx spreadsheet.
47. BH_PSYCHOTHERAPY: use the Medicaid OT Line and set this variable to 1 if the child (CCOULD_ID) ever has a PROC = any of the codes in the “Psychotherapy Procedures” value set in the CCOULD_VSD.xlsx spreadsheet.

Adult-level flags. These flags are to be created in the same way as for the children.