# References

Administration for Community Living, “Aging and Disability Resource Centers,” webpage, last modified December 13, 2017. As of August 1, 2023: https://acl.gov/programs/aging-and-disability-networks/aging-and-disability-resource-centers
Administration for Community Living, “Area Agencies on Aging,” webpage, last modified January 4, 2023. As of August 1, 2023: https://acl.gov/programs/aging-and-disability-networks/area-agencies-aging
Blumenthal David, Anderson Gerard, Burke Sheila, Fulmer Terry, Jha Ashish K., and Long Peter, “Tailoring Complex-Care Management, Coordination, and Integration for High-Need, High-Cost Patients” A Vital Direction for Health and Health Care,” National Academy of Medicine, September 19, 2016.
Chappel Andre, Cronin Kelly, Kulinski Kristie, Whitman Amelia, Nancy DeLew Karen Hacker, Bierman Arlene S., Samantha Wallack Meklir Susan C. Monarez, Johnson Kate Abowd, , “Improving Health and Well-Being Through Community Care Hubs,” Health Affairs Forefront, November 29, 2022.
De Lew Nancy, and Sommers Benjamin D., “Addressing Social Determinants of Health in Federal Programs,” JAMA Health Forum, Vol. 3, No. 3, March 2022.
Dutton Melinda, Osius Elizabeth, Rozario Natassia, and Segal Justine Zayhowski, Working with Community Care Hubs to Address Social Drivers of Health: A Playbook for State Medicaid Agencies, Manatt, 2022.
Gómez Cynthia A., Kleinman Dushanka V., Pronk Nico, Wrenn Gordon Glenda L., Ochiai Emmeline, Blakey Carter, Johnson Ayanna, and Brewer Karen H., “Addressing Health Equity and Social Determinants of Health Through Healthy People 2030,” Journal of Public Health Management and Practice, Vol. 27, Suppl. 6, November/December 2021.
HHS—See Office of Disease Prevention and Health Promotion, U.S. Department of Health and Human Services.
Mayer Victoria, Mijanovich Tod, Egorova Natalia, Flory James, Mushlin Alvin, Calvo Michele, Deshpande Richa, and Siscovick David, “Impact of New York State’s Health Home Program on Access to Care Among Patients with Diabetes,” BMJ Open Diabetes Research & Care, Vol. 9, Suppl. 1, 2021.
Mittmann Helen, Heinrich Janet, and Levi Jeffrey, “Accountable Communities for Health: What We Are Learning from Recent Evaluations,” NAM Perspectives, 2022.
National Academies of Sciences, Engineering, and Medicine, Integrating Social Care into the Delivery of Health Care: Moving Upstream to Improve the Nation's Health, The National Academies Press, 2019.
Nichols Len M., and Taylor Lauren A., “Social Determinants as Public Goods: A New Approach to Financing Key Investments in Healthy Communities,” Health Affairs, Vol. 37, No. 8, August 2018.
Office of Disease Prevention and Health Promotion, U.S. Department of Health and Human Services, “Healthy People 2030: Social Determinants of Health,” webpage, undated. As of August 2, 2023: https://health.gov/healthypeople/objectives-and-data/social-determinants-health
Renaud Jeanette, McClellan Sean R., DePriest Kelli, Witgert Katharine, O'Connor Shannon, Johnson Kate Abowd, Barolin Natalia, Gottlieb Laura M., De Marchis Emilia H., Rojas-Smith Lucia, and Haber Susan G., “Addressing Health-Related Social Needs Via Community Resources: Lessons from Accountable Health Communities,” Health Affairs, Vol. 42, No. 6, June 2023.
Rozansky Phyllis, Maryland’s Local Management Boards: Making a Difference for Children and Families, 1990–2010, Pathways to Results, L.L.C., 2011.
Ruiz David, Kristie McNealy Kristen Corey, Simmermann Jill, Zurovac Jelena, Catherine McLaughlin Mike Barna, and Mleczko Matt, Final Evaluation Report: Evaluation of the Community-Based Care Transitions Program, Centers for Medicare and Medicaid Services, November 2017.
Scharf Deborah M., Breslau Joshua, Nicole Schmidt Hackbarth Daniela Kusuke, Staplefoote B. Lynette, and Pincus Harold Alan, An Examination of New York State's Integrated Primary and Mental Health Care Services for Adults with Serious Mental Illness, RAND Corporation, RR-670-NYSHF, 2014. As of August 31, 2023 http://www.rand.org/pubs/research_reports/RR670.html
Vesley-Massey Kathy, “VAAACares: Partnership Reduces Hospital Readmissions and Saves Money,” CSA Journal, Vol. 1, No. 73, 2019.
Zeigler Bernard P., Redding Sarah A., Leath Brenda A., and Carter Ernest L., “Pathways Community HUB: A Model for Coordination of Community Health Care,” Population Health Management, Vol. 17, No. 4, August 2014.