# Acknowledgments

We are grateful to our sponsor, ASPE, and we thank Amelia Whitman, Bisma Sayed, and Andre Chappel for their support and guidance on this project. We also appreciate the guidance and resources we received from other partners within HHS, including Kristie Kulinski (ACL), Kelly Cronin (ACL), Amanda Cash (ACL), Karen Hacker (CDC), Arleen Bierman (AHRQ/IOD), Aimee Eden (AHRQ), Samantha Meklir (ONC), and Ann Conmy (ASPE). We would also like to acknowledge Jessica Sousa and Sameer Siddiqi for their work on this project in fiscal year 2022. Finally, we would like to thank Len Nichols (Urban Institute) and Melony Sorbero (RAND), Paul Koegel (RAND), and Christine Eibner (RAND) for their review of this report through RAND’s quality assurance process.