# Summary

## Coordination of Health and Social Care

As part of its strategy for addressing the impact of social determinants of health (SDOH), the U.S. Department of Health and Human Services (HHS) is prioritizing the coordination of health and social care services. This strategy is meant to address the historical separation between health care institutions, which provide treatment for medical conditions, and social care, which addresses health-related social needs (HRSNs)—such as access to safe and stable housing, nutritional diets, and transportation—in community settings. In recent years, a variety of policy solutions and interventions have been suggested or implemented to bridge the gap between these two sectors. To explore the landscape of approaches to coordination of health and social care, the Office of the Assistant Secretary for Planning and Evaluation (ASPE) contracted the RAND Corporation to conduct a two-phase project. The first phase, conducted in fiscal year (FY) 2022, examined models of backbone organizations (defined here as organizations designed to coordinate care between the health and social care sectors). The second phase, conducted in FY 2023, focused on Community Care Hub (or Hub) organizations (a specific type of backbone organization that is of particular interest to ASPE and others in HHS).

## Environmental Scan of Backbone Organizations

In the first phase of this study, we performed an environmental scan—which included a literature review and key informant discussions—to explore the variety of backbone organizations that have been implemented or discussed in the policy literature. The literature review covered peer-reviewed literature and grey literature. Key informant discussions were conducted with 14 individuals who either operate backbone organizations or who write about them as policy experts. The backbone organizations examined in the environmental scan can be classified into three groups: government-based, health system–based, or community-based. Government-based backbone organizations, such as the Anne Arundel County Partnership in Maryland, are situated within local government agencies, usually at the county level, from where they coordinate public health activities with health care entities and local communities. Health system–based backbone organizations, such as some Accountable Health Communities and the New York State Health Home model, are situated within health systems or health care payers, from where they identify individuals with HRSNs and coordinate community-based services to address those needs. Community-based backbone organizations, such as AgeSpan in Massachusetts and Partners in Care in California, are situated outside the health care system and act as unified administrative entities for a network of community-based organizations (CBOs) to facilitate care coordination with health care entities.

Across these three types of backbone organizations, four common issues were frequently discussed in the literature as major factors affecting their implementation and success:

- Planning and governance (decisionmaking structures of backbone organizations): Initiatives are governed by nonprofit organizations, leadership coalitions, or contractual agreements involving health care providers, payers, government agencies, and community stakeholders. Mandates stem from federal, state, or local priorities.
- Funding (the sources of public and private finances available to support the coordination of health and social care services within rules and regulations): Funding sources vary by organization, often combining federal funding from the Centers for Medicare and Medicaid Services (CMS) or the Veterans Health Administration with contributions from local health systems, agencies, and philanthropy.
- Data infrastructure (the challenges in sharing management, accountability, and patient care information between health and social care service systems that operate with different levels of resources and data privacy constraints): Lead coordinating organizations typically manage data, including electronic health records, service referrals, and SDOH data. Data-sharing arrangements differ, as does the accessibility of data to health and social care service providers.
- Scope and populations (differences in the services provided and the specific patient populations served): Health services that are coordinated include primary care, behavioral health care, dental care, obstetric care, health education, family planning, and more. Social services that are coordinated include housing, nutrition, public assistance enrollment, substance use treatment, and interpersonal violence support. Initiatives were often implemented at city, county, or regional levels, often in partnership with large health systems. They cover such populations as high health care utilizers, older adults, pregnant individuals, veterans, and those experiencing poverty or homelessness.

Six themes were identified from the key informant discussions:

- Qualities of a good backbone organization: Key informants highlighted the advantage of CBOs as backbone organizations because of their capacity to establish trust with both social service agencies and health care institutions. The success of CBO-based backbone organizations is contingent on aligning their qualities with the collaboration needs of different stakeholders.
- Balancing stakeholder interests: Effective backbone organizations must strike a balance between the requirements of social service agencies and health care institutions. The engagement of social service organizations as equal partners in decisionmaking was emphasized to counter the power imbalance between these entities, ensuring a fair governance structure that promotes coordination.
- Managing data and standardization: A significant consideration revolved around data collection and sharing. Challenges emerged in transferring information across varying systems used by health care and social service providers. Standardizing data collection and integration emerged as a key solution to enhance coordination. Discussions underscored the need for uniformity to facilitate program evaluation.
- Funding challenges and longevity: Key informants stressed limitations in billing for Medicare, uneven funding distribution between health care and social services, and the necessity of blending funding from multiple sources. Informants emphasized funding access for social workers and community health workers for their role in coordination.
- Government support and policy influence: Informants highlighted such mechanisms as Medicaid section 1115 demonstrations, which offer flexible funding. Leadership support at various government levels was seen as instrumental in fostering a conducive policy environment and garnering financial and administrative backing for backbone organizations.
- Telehealth’s evolving role: Informants discussed telehealth’s potential to enhance access and overcome barriers, especially during the COVID-19 pandemic. Informants noted the benefits that telehealth could have for remote screening and care and called for sustaining regulatory changes that expanded access to these services.

## Community Care Hubs

In the second phase of this study, we focused on one type of community-based backbone organization, known as a Hub. Hubs are nonprofit organizations that provide a centralized administrative and operational interface between health care institutions and a network of CBOs that provide social services. As shown in Figure S.1, Hubs serve as a single point of contact between health care entities (which might be payers or provider organizations) and a network of CBOs that provide social services. To describe how Hubs are being implemented in practice and the factors that are influencing their operations, we conducted case studies of six Hubs. The case studies were used to compare Hubs with respect to their (1) development and structure; (2) community engagement and governance; (3) community, health care, and government partners; (4) health information systems; and (5) financing. Leadership of each Hub were also asked about potential policy changes that would enhance the Hub’s ability to operate successfully.

Figure S.1 The Community Care Hub Model

### Development and Structure

Hubs developed from preexisting organizations with experience coordinating health and social care and often had an originating or parent CBO. Five of the six Hubs were developed by Area Agencies on Aging (AAAs).^1^ Several Hubs had also participated in CMS’s Community-based Care Transitions Program (CCTP).^2^ Reflecting this background, the services provided by the Hubs initially focused on coordinating care for older adults during hospital-to-home transitions for patients for a limited geographic area. Over time, however, the Hubs have incrementally expanded the populations they serve, the services they coordinate, and the geographic regions they cover. Although the Hubs share a general structure for linking health care and social services, there are differences in their operations. Some Hubs, such as VAAACares^®^, operate as a separate program within the organization that also houses the AAA from which it developed, although they remain formally separate from those AAAs. Others, such as Western New York Integrated Care Collaborative (WNYICC), were established as independent organizations. Hubs also differ in the extent to which they work directly with CBOs in their networks: Some Hubs have direct relationships with CBOs, some work through existing AAAs (creating a “network of networks”), and some have a combination of both approaches. Patient identification processes also differ: Some patients are identified by Hub or hospital staff during the patient’s hospitalization, while others are identified through claims data or discharge lists received by the Hub from payers. In one Hub, CBOs can make initial referrals into the Hub, which can connect them with other CBOs or health care partners.

### Community Engagement and Governance

According to our discussants, Hubs offer potential benefits for communities by providing opportunities to have input into health care priorities and care delivery organization. Hubs build networks of CBOs that are attuned to immediate community needs, especially in underserved communities (such as communities of color and immigrant communities). Governance boards are a key way to ensure community input on policies.

We found three predominant models of governance. In the first, Hubs relied on their parent or originating CBOs for their governance boards, without creating a separate governance board for their Hub activities. In the second model, a new governance board was created for the Hub, which included representatives from network CBOs and representatives with health care experience. In the third model, the Hub relied on several boards, with separate boards created for each participating county in which the Hub operates. According to Hub discussants, these models enable them to represent local community perspectives, prioritize needs, and enhance community involvement in decisionmaking processes.

Among the Hubs that we examined, none had a formal community governance board that was specific to the Hub, but all six had structured ways to incorporate community input into Hub policy. Several Hubs predominantly relied on advisory boards that do not have decisionmaking authority to gather feedback from constituents and members of their patient population. In addition, some Hubs had not expanded their community member engagement to the same reach as their Hub activities. Instead, their community member input predominantly came from individuals in the typical service area of their parent or originating CBO.

### Community, Health Care, and Government Partners

All the Hubs maintain and support a network or multiple networks of CBOs that can provide a wide variety of social care services across the geographic regions in which the Hub operates. Hubs form membership agreements with member CBOs that authorize the CBOs to participate in network activities (such as training programs and policy meetings) and to provide and be reimbursed for services delivered to individuals covered by contracts that the Hub enters into with health care entities. The Hubs developed these networks starting with the CBOs they had histories of working with prior to becoming a Hub and expanding through recruitment of new CBOs. Hub leadership described the expansion process as following a “friends-of-friends” model, in which new CBOs were recommended by existing network members. Hubs emphasized the importance of vetting potential new CBO partners—through discussions with leadership and site visits—for the CBO’s ability to provide and document care.

Hubs establish contractual relationships to coordinate social care with health care entities, including payers and health care providers. Payers such as Medicare Advantage plans, Medicaid managed care organizations, and commercial insurance plans were among their partners. In the case of at least one Hub, their contracts initially covered only specific populations, such as a payer’s Medicare beneficiaries. Over time, according to our Hub discussants, the payers came to appreciate the value of the Hub’s work and expanded their contracts to cover all health plan members. Hubs also discussed establishing formal contracted relationships with hospitals, health systems, and medical practices to coordinate care for high-risk patients. However, relationships with skilled nursing facilities, rehabilitation facilities, and primary care practices tended to be more informal. Some Hubs faced challenges in establishing contracting relationships with health care providers because some providers preferred creating their own internal programs to coordinate health and social care.

Hubs collaborate with government partners at the federal, state, and local levels. At the federal level, CMS and the Administration for Community Living (ACL) were mentioned as sources of funding, networking, and technical assistance. Several Hubs started under CCTP and continued with other CMS programs. Parent CBOs of Hubs interact with their local Medicaid offices, including through their state Medicaid waiver programs, which allow Medicaid to pay for home and community-based services for eligible individuals. Hubs also participate in various initiatives led by ACL (such as ACL’s Community Care Hub National Learning Community) and connect with other Hubs through these programs. At the state and local levels, Hubs have formal partnerships or relationships with public health departments, city or county governments, state departments of health, Medicaid agencies, and housing agencies. These partnerships support Hubs by setting standards and providing access to services, but the relationships are often ad hoc without a dedicated office or agency focused on working with Hubs and their networks.

### Information Systems

Much of the work of the Hubs involves managing information, providing a connection between non-interoperable information technologies on the health care and CBO sides of their work. Hubs have developed electronic record systems to coordinate and document care provided by the CBO networks. However, the interfaces between the Hubs and their health care partners remain complex and disconnected from the CBO networks, requiring, in many cases, manual data entry for billing or health information. These challenges are magnified by differences across payers’ information systems and reporting requirements. Hubs also lack access to information on the health and health care of the individuals that they serve beyond what they gather and the information shared with them for referral purposes, which makes understanding the impact of their work on health outcomes difficult.

### Financing

The financing of Hubs follows a common development sequence, starting with external funding for startup from foundations, federal grants during early development, and later transitioning to contract support for ongoing operations. Hub leadership emphasized the importance of transitioning from reliance on grant funding, which is unpredictable, to contract funding, which is more stable. Contracts generally provide for payments from health care entities, which the Hubs pass along to CBO service providers, keeping a percentage to support Hub operations. Most Hubs are paid following a fee-for-service model, but some are being paid through alternative payment models, in which fixed payments are made per patient or intervention. CBOs in the Hub networks receive payments for their services from the Hub, and they can blend and braid that funding with other sources of revenue for additional services they provide to individuals referred through the Hub. Blending and braiding of funding at the CBO level is also used by some Hubs to fund services not covered by the health care contracts held by the Hub. A few Hubs noted that they were concerned that this practice might indirectly subsidize health care organizations that benefit from the care provided by CBO social care service providers that is not paid for through their contracts.

### Policy Challenges and Suggested Opportunities Identified by Hub Leadership

In our discussions with Hub leadership, we asked discussants to identify policy changes that would enable them to operate more effectively and efficiently. Their recommendations address three general topics: information systems, payment systems, and other regulatory changes.

- Information systems: Discussants highlighted the need for simplified data collection and billing operations to better manage health care contracts. They suggested that the government should invest in data infrastructure for CBOs to enable direct reporting from service providers and proposed regionwide social care data platforms to standardize methods for referral tracking and increase transparency. Bridging the gap between health care and CBO information systems through guidelines for information-sharing was also recommended. Improved quality measurement using health information systems and standardized performance metrics were seen as beneficial for assessing care and enabling alternative payment models.
- Payment arrangements: Overall, Hubs made two financing suggestions: (1) providing startup funds for network development to address information technology (IT) development and initial staff hiring and (2) promoting alternative payment models for Hubs to offer flexibility and accountability for quality and outcomes of social care services. Federal and state policies were seen as catalysts for shifting from fee-for-service to alternative payment models.
- Other regulatory changes: Hubs proposed standardizing contractual arrangements and workflow between Hubs and health care entities to bring consistency and predictability to their operations within regions and states. From the Hub perspective, standardized contract arrangements would reduce the burden of developing new contracts with each health care entity with whom they work. The Hubs also raised the idea of setting quotas for minimum referrals from health care entities to Hubs (based on anticipated need) to better predict caseload size. One Hub also raised a concern about a proposed federal rule that would require AAAs to disclose details of contracts with health care entities to State Units on Aging. Because those contracts include proprietary information covered by nondisclosure agreements, this rule would require separation between Hubs and AAAs, which would be a costly and wasteful process, according to our discussant.

## Conclusions

The following are our general conclusions across both phases of the project:

- Alignment, facilitation, and coordination: Many backbone organizations, including Hubs, aim to fulfill three functions—alignment, facilitation, and coordination. Alignment involves developing shared knowledge and norms across a group of internal partner organizations. In the case of Hubs, this would involve aligning among CBOs within the network about what kinds of care and assessments are expected, which can improve the capacity of CBOs to address complex needs. Facilitation refers to the development of protocols and pathways to provide concurrent care by multiple providers, while coordination involves actively managing complex care at the individual level. The degree of alignment that can be achieved may be affected to a certain extent by the type of entity that is serving as a backbone organization. The strength of Hubs, compared with other types of backbone organizations, is related to alignment (i.e., their ability to organize networks of CBOs and provide the necessary bridging services that enable coordination of care across sectors).

The following are our conclusions specific to Hubs:

- Challenges of community involvement: Engaging the communities in which patients live is an important component of addressing HRSNs. Hubs differ from other backbone organizations by being located outside the healthcare system and having strong connections with CBOs. However, even for the Hubs, formalizing governance structures and including community representatives in setting policy priorities remains challenging. Additionally, a one-way referral flow from health care entities through the Hubs to CBOs is common, limiting the ability of CBOs to influence care for individual community members.
- Hubs face familiar challenges: The literature on backbone organizations consistently highlights challenges that these organizations face with respect to IT and financing. Challenges related to IT and financing are common in Hub operations. The lack of quality measures hinders accountability and the ability of Hubs to negotiate more flexible payment models.
- Lessons for future studies: Further investigation is needed to understand the impact and role of Hubs and other types of backbone organizations in health and social care coordination. Given the focus of Hubs on high-cost, medically complex patients, evaluations of their impact should focus on outcomes with clear relevance to this population. The observations from this study come primarily from six case studies, supplemented by an environmental scan and key informant discussions, so results might not generalize to other organizations and settings.

1 AAAs are state-designated agencies that coordinate and offer services to address the needs of older adults in specific geographic regions and allow them to remain in their homes. AAAs can be public, private, nonprofit, or quasi-governmental organizations (Administration for Community Living, 2023). These organizations work to help older adults remain in their homes by helping coordinate their care and services. Many AAAs also run Aging and Disability Resource Centers, which are part of the No Wrong Door model to streamline access to long-term services and supports for key populations, including older adults, people with disabilities, and their families (Administration for Community Living, 2017).

2 CCTP was launched by CMS in 2012 and aimed to improve quality and patient experience and reduce costs associated with care transitions. The five-year program provided funding to CBOs to establish partnerships with hospitals and other health care providers to improve high-risk Medicare beneficiaries’ care transitions. Participants paired existing care transition models with additional social services and supports to reduce readmissions (Ruiz et al., 2017).