# About This Report

The U.S. Department of Health and Human Services (HHS) is prioritizing efforts to coordinate health and social care services as part of its strategy for addressing social determinants of health. These efforts are aligned with other HHS policies that incentivize health care providers to screen patients for health-related social needs (HRSNs). HRSNs are social needs, such as lack of transportation or unstable housing, that can affect health outcomes. For patients screening positive for one or more HRSNs, better coordination between health and social care providers can help facilitate connecting such patients with relevant social care services that can address their needs. To better understand current approaches to health and social care coordination, the Office of the Assistant Secretary for Planning and Evaluation (ASPE) contracted with the RAND Corporation to examine the innovative approaches to coordinating health and social care services. This report presents the findings of a two-phase project examining backbone organizations that coordinate health and social care service sectors. The first phase, performed in fiscal year 2022, involved an environmental scan of alternative models for coordinating health and social care services, whether based in the health system, government, or community. In the second phase, we focused on community-based backbone organizations, particularly an emerging model, known as a Community Care Hub, or Hub. Hubs are independent organizations that serve as a single point of contact between health care entities (including payers and health care delivery systems) and a network of community-based organizations that provide social services addressing HRSNs. To study Hubs, we conducted a series of six case studies, outlining similarities and differences in how Hubs address common challenges in coordinating health and social care services.

## RAND Health Care

This research was funded by the Office of the Assistant Secretary for Planning and Evaluation, U.S. Department of Health and Human Services and carried out within the Access and Delivery Program in RAND Health Care.

RAND Health Care, a division of the RAND Corporation, promotes healthier societies by improving health care systems in the United States and other countries. We do this by providing health care decisionmakers, practitioners, and consumers with actionable, rigorous, objective evidence to support their most complex decisions. For more information, see www.rand.org/health-care, or contact

RAND Health Care Communications

1776 Main Street

P.O. Box 2138

Santa Monica, CA 90407-2138

(310) 393-0411, ext. 7775

RAND_Health-Care@rand.org