# Looking Forward

The conditions in the environments where people are born, live, learn, work, play, worship, and age affect a wide range of health, functioning, and quality-of-life outcomes. At the community-level, these social determinants of health influence a variety of individual social needs such as financial strain, unstable and poor-quality housing, food insecurity, lack of access to health care, and inadequate educational opportunities that can have consequential implications for health outcomes. Addressing these needs is critical to ensuring equitable opportunities exist for all Americans to be able to achieve their optimal health and well-being.

Over the course of the next year, HHS will continue to invest in Hubs through an ACL grant award for a Center of Excellence (COE) to Align Health and Social Care, which will re-grant funding to support the operational infrastructure of approximately 20 Hubs across the country. The COE and its grantees will also participate in an external evaluation of Hubs to further assess impact of this model. A Community Care Hub National Learning Community will launch in December, offering up to 30 organizations the opportunity to gain access to vital peer support, individual and group technical assistance from national experts, and up-to-date information on resources and initiatives aimed at furthering the capacity of Hubs nationwide.

Based on experience to date, community care hubs appear to be a promising model for coordinating health and social care services that has proven to be sustainable in practice and of interest to health care entities and CBOs alike. This model is worthy of further attention and evaluation to better understand the specific characteristics of Hubs that contribute to success based on their goals and within the context of the communities they serve.