# What We Learned from This Report

From the first phase of this project, we learned that there is an array of backbone organizations operating in various locations across the country that can facilitate coordination between health and social care providers. These include organizations that are operated by government entities, health systems, and CBOs stemming, in part, from the unique circumstances and histories of the local environments in which they operate. They vary in the processes by which they are governed, how they are funded and operate, their approach to care coordination, who they serve, and the nature of their interactions and relationships with other partner organizations. Key informants discussed the advantages of CBO-led backbone organizations because of their potential capacity to establish trust with both social service agencies and health care institutions, and their potential to elevate the collective influence of smaller CBOs when interacting with larger health care institutions. Informants noted that their success is dependent on their ability to align themselves with the collaboration needs of other stakeholders.

From the in-depth case studies of Hubs conducted in the second phase of this project, we learned that these Hubs varied significantly along a number of dimensions but shared a similar sense of mission to uplift the people in the communities they serve. Other common themes reported by the Hubs included being able to combine trust from the community with administrative and technological sophistication to interact with health care entities and that they empowered other CBOs to have a “seat at the table” with health care entities.

Among the Hubs included in our study, many of them had their origins in Area Agencies on Aging, which are state-designated agencies that coordinate and offer services, typically through a network of service providers to address the needs of older adults in specific geographic regions to allow them to remain independent in their homes and communities. However, a number of these Hubs have since expanded the types of populations they serve beyond the elderly, the types of services they coordinate, and the geographic regions they cover. They reported having different types of relationships with the CBOs in their networks, which varied from direct interactions to working through a “network of networks” (i.e., coordinating with other CBO networks operating in different areas or serving different populations). How they identify individuals also varied, from directly identifying patients at partner health care institutions, to using claims data provided by health care partners to identify those who could benefit from their services, to receiving rosters of potentially eligible patients who have been recently hospitalized that might benefit from their services to ensure safe transitions back to their homes and communities. They varied in their governance models with different approaches to incorporating community input. They reported relying on different types of funding sources as they matured, often benefiting from startup funds awarded by foundations and federal grants and transitioning over time to receiving most of their funding from health care partner contracts in addition to ongoing sources of social services funding which enabled them to serve a greater proportion of individuals in need.

A common theme among the Hubs we met with was challenges related to interoperability of their information technology systems with those of their health care partners and member CBOs, often requiring manual data entry to share information across organizations. They reported that health care payers and providers generally have sophisticated information systems, while individual CBOs vary widely in their ability to report and share information. A number of the Hubs also reported not being able to obtain information on the health and health care of the individuals they serve beyond the information they receive for referral purposes, making it challenging for them to assess some of the ultimate impacts of the services they provide.

The Hubs suggested a number of potential actions that could help support their success such as:

- Establishing standardized contractual arrangements;
- Reducing the complexity of data collection and billing operations required by health care contracts;
- Providing funding for data sharing infrastructure;
- Developing guidelines for information sharing between health care entities and Hubs;
- Establishing standardized performance metrics and otherwise improving quality measurement; and
- Promoting alternative payments models that offer flexibility and accountability for the quality of service delivery.