# Why We Commissioned This Report

The U.S. Department of Health and Human Services (HHS) envisions a future in which all individuals, regardless of their social circumstances, have access to aligned health and social care systems that achieve equitable outcomes through high-quality, affordable, person-centered care. This vision is based on the recognition, documented through a wide body of research, that unmet social needs can affect a wide range of health, functioning, and quality-of-life outcomes and it is aligned with HHS’ Strategic Approach (https://aspe.hhs.gov/sites/default/files/documents/aabf48cbd391be21e5186eeae728ccd7/SDOH-Action-Plan-At-a-Glance.pdf) to Addressing Social Determinants of Health to Advance Health Equity. Other documents related to the Strategic Approach can be found here (https://aspe.hhs.gov/topics/health-health-care/social-drivers-health/addressing-social-determinants-health-federal-programs).

This report is being released in tandem with the U.S. Playbook to Address the Social Determinants of Health (https://www.whitehouse.gov/wp-content/uploads/2023/11/SDOH-Playbook.pdf) and an HHS Call to Action (https://aspe.hhs.gov/reports/hhs-call-action) intended to catalyze efforts at the community level to address social needs through cross-sector partnerships across health care, social care, public and environmental health, government, and health information technology organizations. The report is the result of a two-year project that ASPE (in partnership with the ACL) commissioned RAND to undertake, to better understand existing approaches to coordinating health and social care services, with a focus on one particular model, community care hubs (Hubs). Hubs are community-focused entities that support a network of community-based organizations (CBOs) providing services to address social needs that can affect health outcomes. These Hubs support their members by centralizing administrative functions in contracting with healthcare organizations.

As part of HHS’ approach to addressing social determinants of health,^1^ agencies across HHS are implementing policies and programs to support community-led transformation to develop well-coordinated systems of health and social care, to better address unmet social needs. For instance, the Centers for Medicare and Medicaid Services (CMS) is implementing health care program payment policies designed to drive health care professionals toward routine screening for unmet social needs and, in some instances, allow payment programs to cover the cost of certain services to address housing instability, food insecurity, and lack of transportation. Such policies represent critical initial steps to addressing social needs identified in health care settings. However, without an organized system in place to facilitate referrals to social care providers, track if and when social services are delivered, and determine whether an individual’s needs have in fact been met, there is a risk of building a potential bridge to nowhere. While well-intentioned, this falls short of achieving the underlying objective of improving the social circumstances that are impacting an individual’s health. Backbone organizations that help facilitate coordination between the health and social care sectors, such as Hubs, can serve as the connective tissue within a community to ensure these needs are met.

Through the work of the first phase of this project, we set out to gain insights into the various forms of backbone organizations that exist in the field, including how they are structured, challenges they face, and approaches they apply to overcome these challenges. In the second phase of this project, we focused specifically on Hubs as a promising model with the potential to support CBOs in their interactions with the health care sector. We commissioned RAND to conduct a series of six case studies of a diverse set of Hubs to better understand: (1) how they may be structured, (2) approaches they use to incorporate community input into their decision making, (3) what types of organizations they partner with to achieve their strategic objectives, (4) the information technology infrastructures they employ to manage referrals, track service provision, and monitor outcomes to improve service delivery, (5) financing sources for their operations, and (6) policy changes identified by Hubs that would enhance their ability to operate successfully.

1 The U.S. Department of Health and Human Services defines social determinants of health as “the conditions in the environments where people are born, live, learn, work, play, worship, and age that affect a wide range of health, functioning, and quality-of-life outcomes and risks.”