# Chapter 4 Conclusions

The first phase of this study examined the broad range of backbone organizations that have developed in recent years, all with a common aim of better addressing HRSNs by actively coordinating the work of health care providers and social services agencies located in the communities in which patients live. The backbone organizations differ from each other in many ways but first and foremost in where they are located institutionally: Some are located within health care entities, some within governmental organizations, and some in community organizations separate from both health care and government. Other key features that distinguish backbone organizations, according to the literature and our key informant discussions, relate to how they collect and share information, how they are financed, and the extent to which they give social services providers and other community stakeholders a role in how HRSNs are met.

The second phase of the study examined community-based backbone organizations, also known as Hubs. The Hubs that we examined—five in operation and one in development—are addressing some of the barriers to linking health care and social services sectors that have been described in the literature. The Hubs’ growth over time and continued operational success in contracting with payers and health care systems suggests that they are successful in achieving outcomes desired by their health care partners. In addition, their continued success in contracting suggests that they are providing a sustainable source of referrals and revenues to their CBO networks while also sustaining their own operation. However, according to our discussants, the issues of information-sharing and financing remain ongoing points of concern that could be addressed through policy changes. In this concluding chapter, we provide some observations regarding how the Hubs are addressing the challenges that other organizations that attempt to coordinate health and social care services also face, and we highlight potential strategies for future studies to examine the impact of the Hub model.

## Limitations

Findings from this series of case studies should be interpreted in light of its limitations. First, the operational success of the Hubs that we describe (i.e., their growth in contract partners and geographic reach) cannot be interpreted as evidence of their impact on outcomes or costs of care. We were not able to identify any carefully controlled independent studies of Hub outcomes in the literature search. Second, we were able to include only six Hubs in this study. The six were selected from the 58 organizations that are participating in ACL’s national learning collaborative, which is the best available listing of such organizations. Given the role of ACL in supporting Hubs, it is likely that a majority of the Hubs in operation in the country are participating in one of the ACL learning collaboratives. However, sampling from organizations participating in the learning collaboratives might have made it more likely that we selected organizations with stronger ties to ACL. The six Hubs that were included vary in their size, in the region of the country in which they are located, and in the ways that they developed out of preexisting organizations. Moreover, the consistency of the issues that arose in the case studies suggests that similar issues would have arisen with a different sample. Third, data collection was limited to semistructured discussions with Hub staff. We were not able to conduct detailed audits of Hubs to examine contracts, to discuss Hub operations with CBOs or service users, or to independently assess processes or outcomes.

## Alignment, Facilitation, and Coordination

Our Hub discussants described the Hubs as fulfilling three important functions related to the connection between health and social care services: alignment, facilitation, and coordination.

Alignment refers to the development of shared knowledge of operational capacities and goals; expectations regarding workflow, documentation, and outcomes; and norms for communication between partners. Much of what the discussants described as the Hub’s ongoing work of organizing networks of CBOs, including providing training on business acumen, IT, and quality measurement, contributes to alignment of the CBO sector to the requirements of the health sector partners. The descriptions by the Hub leaders suggest that these efforts might have significant positive effects on the capacity of local social service agencies to deliver services and to address complex needs of individuals in their communities living with functional impairments because of medical conditions. However, without direct studies of the impact of Hubs on social services systems in the communities in which they operate, we cannot draw firm conclusions on this point.

Facilitation refers to the development of actual protocols and pathways, tested through repeated practice, through which patient care can be concurrently provided and managed by multiple provider organizations. Hubs are facilitating care by filling in the information processing gaps between CBO and health care information systems, managing payments from payers to CBOs, and distributing referrals across the CBO network.

Coordination refers to the active management of complex care provided by multiple agencies at the individual level. Hubs are coordinating care by providing comprehensive assessments to identify needs and arranging for the full range of available services to address those needs. Although each of these functions is compellingly described, evidence from this study is not sufficient to determine the extent to which Hubs are the most effective means of accomplishing these goals. Moreover, we did not find studies to address this question empirically in our literature review.

Combining these three functions, Hubs might be capable of addressing some limitations that have been identified in studies of other models for coordinating health and social care services.

An example is the recent evaluation of the AHC model, which focuses on identifying individuals with HRSNs in health care settings and connecting them with social services (Renaud et al., 2023). The evaluation found that the AHCs were successful in identifying large numbers of individuals with HRSNs. However, the evaluation also found that the navigation services provided to these individuals did not increase their connections to community services, because of low capacity and mismatch between identified needs and available community services. The ability of Hubs to align CBOs and develop pathways for coordinating care might address the barriers identified in the AHC evaluation.

## Hubs Still Face Challenges with Information Technology and Financing

Although the Hubs are connecting health and social care service sectors, they still face the challenges identified in the environmental scan. Two challenges identified in prior literature regarding IT and financing were also two of the most commonly discussed challenges to Hub operations in our case studies. Some discussants also highlighted the lack of accepted quality measures for their work even though there are quality measures for some of the work that Hubs do, such as transition care. More work is needed to identify specific gaps in measurement and potential barriers to use of existing measures.

It is important to note that the challenges described by our discussants are interrelated. IT limitations make the work of Hubs less efficient and precise—thereby raising costs—and hinders measurement of the quality of care. Lack of accepted quality of care measures, as described by our discussants, hinders the ability of the Hubs to demonstrate accountability to contractors or the community and to make targeted efforts to make improvements. Without accepted measurement and quality improvement, payers are more likely to insist on fee-for-service payment arrangements and less likely to offer more-flexible, less burdensome payment models.

## Hubs and Community Engagement

One of the major motivations behind the Hub model is the connection between Hubs and the communities in which they are located. CBOs that provide social services to a community tend to be trusted and respected by that community, partially because of their efforts to represent community interests. One of the potential advantages noted of the Hub model is that it provides representatives of underserved communities a seat at the table in discussions of how patients’ HRSNs should be met. In practice—as evidenced by the Hubs we examined—Hubs are, in fact, relatively well-connected to their communities compared with the health care entities that they contract with. Many of the Hubs have historical roots in organizations, such as AAAs, that were primarily focused on local community-based services. However, structural connections with communities remains challenging for Hubs in many respects. First, with respect to Hub governance, connections between communities and Hubs are not generally formalized in governance structures that would provide legal accountability to community representatives. All the Hubs we examined have advisory roles for their CBOs, and some have advisory groups that include community representatives. However, none of the Hubs we examined give these organizations a formal role in setting organizational policy priorities the way that a governing board of a nonprofit organization does. Inclusion of community representatives becomes more challenging as the Hubs grow to cover more communities across larger geographic areas. Second, among the Hubs we examined, there was a tendency for patients to be identified primarily or exclusively by the health care entity (i.e., a one-way referral flow from the health care entity into the CBO network). Movement in the other direction (i.e., people with needs identified in the community being referred to the Hub for coordinated health and social care), was much less common. In the Hubs we examined, the health care entity effectively serves as a gatekeeper to Hub services.

The extent of community engagement and governance is one of the ways that Hub models for coordinating health and social care services vary. Some models envision the backbone organization broadly as a structure for communitywide investment in health and well-being, bringing diverse stakeholders together for public health planning (Mittmann, Heinrich, and Levi, 2022). A model for this type of backbone organization was proposed by Nichols and Taylor (2018) and suggests that communitywide interests in improving health outcomes can motivate collaborative integration efforts across diverse stakeholders. Other models are more narrowly focused on targeted services for a smaller population with higher levels of medical need (Blumenthal et al., 2016). The Pathways Community HUB Institute model, which emphasizes that each member should receive a specific set of services defined by a standard “pathway,” is an example of a more narrowly focused approach (Zeigler et al., 2014). Although there was variation across case studies, the Hubs we examined are closer to the latter, narrow model than to the former, broad model.

## Lessons for Future Studies

The Community Care Hub model is a promising model for coordinating health and social care services that has proven to be sustainable in practice and of interest to health care entities and CBOs alike. Further investigation of Hubs’ role in health and social care service provision and their impact on population health is clearly warranted. Future studies would benefit from investigating the perspectives of CBOs participating in Hub networks and payers that contract with or are considering contracting with Hubs. To advance understanding of Hubs and their impacts, it will be important to clarify the goals that Hubs are meant to address and to evaluate their impact on those goals relative to other approaches to coordination of health and social care. Most importantly, it will be important to determine whether Hubs are seen broadly as communitywide collective responses to health and HRSNs for vulnerable individuals and populations or seen narrowly as facilitators of health care efforts to lower costs and improve outcomes by addressing HRSNs for high-cost beneficiaries. Determining the goals of Hubs is critical for defining the outcomes of evaluation studies that can provide evidence on their impact. Research that clearly defines these goals and assesses the ability of Hubs to achieve them can provide policymakers with the information needed to support their role in addressing HRSNs.