# Chapter 3 Community Care Hubs in Practice: Six Case Studies

In this chapter. we present the results from case studies, highlighting similarities and differences in how the Hub model has been implemented and the perspectives of Hub leadership. The results are divided into five areas: (1) the development and structure of the Hubs, including the services they provide and the populations they cover; (2) community engagement and governance; (3) partnerships that Hubs have with CBOs, health care entities, and government agencies; (4) information-sharing; and (5) financing. In the final section of this chapter, we summarize the discussants’ recommendations for policy changes that would facilitate the work of the Hubs.

## Case Study Methods

We selected six case studies from the 58 organizations participating in the ACL Community Care Hub National Learning Community. The goal was to arrive at a sample of six Hubs that vary with respect to geography, size, and stage of development. One of the initially selected Hubs declined to participate because it did not consider itself a Hub and was replaced by an alternate. Figure 3.1 shows the location of the six Hubs that participated in the study:

- Virginia Area Agencies on Aging—Caring for the Commonwealth (VAAACares^®^), headquartered in Urbanna, Virginia
- Community Care Solutions, headquartered in Dothan, Alabama
- Direction Home Akron Canton Area Agency on Aging and Disabilities (DHAD), headquartered in Uniontown, Ohio
- Houston Health Department, headquartered in Houston, Texas
- Partners at Home, headquartered in Los Angeles, California
- Western New York Integrated Care Collaborative (WNYICC), headquartered in Buffalo, New York.

Information for the case studies was compiled using documents available online and discussions with Hub leadership. Prior to contacting the Hub, the research team reviewed Hub websites and conducted searches for descriptions of each Hub in published peer-reviewed and grey literature. Discussions were then held with Hub staff, following the discussion guide presented in Appendix B. Initially, contacts were made with the leadership of each Hub to discuss participation in the study. Hub leadership were informed of the topics to be covered and were asked to help arrange discussions with the appropriate staff in their organization with the relevant expertise and experience. Multiple discussions with each Hub were conducted as needed to cover all topics in the discussion guide. For instance, separate discussions were held with staff from DHAD to cover overall structure of the Hub and its services, IT, and financing. Between two and four discussions were held with each Hub.

Figure 3.1 Map of Included Community Care Hubs

A case study template was used to combine the information from the document review and discussions into case study summaries, which are presented in Appendix C. Draft summaries were shared with the Hub leadership for their review, and Hub leadership provided corrections and additional details that were added to the summaries. All members of the team then reviewed the case study summaries and, through discussions, identified the main points of similarities and differences across Hubs within each of the major topic areas.

## Development and Structure

The six Hubs in our sample have developed along similar trajectories. Each of them was formed by an originating or parent CBO that had taken on a role as a network backbone organization as part of a state or federal policy initiative focused on social care. Through these programs, these pre-Hub backbone organizations had their first experiences contracting with health care entities to provide linkage between health care and social services, generally focusing on a particular population, most commonly older individuals. Through these early contracts, the organizations developed skills in contracting, organizing community-based services to meet contracting terms, and managing payments from health care entities to their network CBOs. In addition, contracting provided a more stable and sustainable source of financing than the grant-based work that the organizations had previously relied on. Following from that experience, the organizations sought out new contracting opportunities that enabled them to provide services beyond their initial scope of practice. Continuing success in contracting led to expansion of the health care entities that they contracted with, the services that they coordinated, and the populations and regions that were covered by the contracts. In some cases, the Hub was formed as a distinct program within the existing CBO in which it developed; in others, the Hub was formed as a new independent nonprofit organization with its own administrative and governance structures.

Five of the six Hubs in our sample have roots as AAAs.^3^ Of those five, all four of the operational Hubs were nonprofit AAAs; the fifth, the Houston Health Department (which is still in its planning stages), is a AAA located in a local government agency and is now planning to house its Hub outside the government in an affiliated nonprofit agency. Staff at DHAD highlighted the value of having a AAA act as Hub by emphasizing that they have long held “the role of assessing need, providing information, referrals, and support to people across programs,” which “helps ensure barriers and gaps are met outside of the patient’s transition needs.”

Three of the Hubs with roots in AAAs had their first experiences as a backbone organization through the CMS Community-based Care Transitions Program (CCTP).^4^ The one Hub that was not a AAA shared with the other Hubs an origin in an innovative policy initiative: Partners at Home had its first experiences as a backbone organization as part of a nursing home diversion program that was part of a Medicaid waiver and that also participated in the CCTP.

Once these organizations had their first experiences as backbone organizations, they expanded incrementally into their current form as Hubs. For instance, the three AAAs that had participated in the CCTP program continued to contract for care transitions with payers and health care providers after the CCTP program ended. Medicare Advantage plans were prominent among their initial contracting partners, although they have since developed more diverse health care partners, including Medicaid payers, commercial health plans, and health care providers. WNYICC, which was formed by two AAAs and did not participate in the CCTP program, began with contracts with Medicare Advantage plans, serving a population similar to the ones they had previously served as AAAs, before expanding to contracts with Medicaid payers. Similarly, Partners at Home’s initial local Medicaid contracts led to contracts across the state with Medicaid payers.

The foundation of these organizations in transitional care for older adults is reflected in the kinds of services that they currently coordinate as Hubs, as shown in Table 3.1. All the Hubs provide hospital-to-home transition services. Most also provide services that address food insecurity, such as prepared meals (including medically tailored meals) or nutritional support. Three of the six Hubs provide transportation and housing services, and two indicated that they provide other services, such as a falls prevention program that includes a home walkthrough and retrofitting of the home to reduce the chance of falls and diabetes education and support classes that support beneficiaries in making better food choices.

Table 3.1 Services Provided by Hubs

Hub | Hospital-to-Home Transition | Meals/Food Security | Transportation | Housing | Other
VAAACares | x | x | x | x
Community Care Solutions | x | x | x | x | x
WNYICC | x | x
Houston Health Department | x
Partners at Home | x | x | | x
DHAD | x | x | x | x | x

The five Hubs in our sample that are currently operational have also expanded geographically as they expanded the breadth of their contracting activities and the populations they serve. Three of the Hubs (VAAACares, DHAD, and Partners at Home) operate statewide in their states of origin, and two of them (VAAACares and Partners at Home) have begun expanding outside those states. Community Care Solutions and WNYICC have also expanded, but both remain more focused on their region of origin. For the Hubs created by AAAs, increased networking with other AAAs in their states has led to subcontracting arrangements and regional growth.

All six Hubs have the same general structure for linking health and social care services, but there are important differences in how they operate. First, there are some slight differences in the extent to which the Hubs interact directly with the CBOs in their networks or indirectly through other AAAs that organize local networks. WNYICC and VAAACares are examples of Hubs that work directly with their member CBOs. For instance, VAAACares vets each individual CBO in its network, often making onsite visits prior to including the CBO in the network. DHAD and Community Care Solutions rely on their network of AAAs to provide services in the regions in which they operate or to identify local CBOs and manage referrals to those CBOs in cases in which the AAA itself does not provide those services.

Second, for all the Hubs, a majority of the patients they serve are identified by the health care entity that they are contracting with, but there are differences in how this process works. For some, such as VAAACares, patients are identified while hospitalized so that a transition coach affiliated with VAAACares can meet with them prior to discharge for an evaluation. The coach then follows up with the patient at home for a home-based assessment to identify additional needs. DHAD has a similar process to VAAACares: Their contracted health plan sends regular rosters of potentially eligible patients who have had recent hospitalizations and that could benefit from the Hub’s acute care transition program, in which it conducts needs assessments and helps coordinate any services that could address the patient’s potential HRSNs. Additional patients are also found through the DHAD’s participation in hospital Ground Rounds, in which the Hub’s registered nurses (RNs) who serve as health coaches can learn about other high-risk individuals who might benefit from the Hub’s work and are eligible for services based on their contract. The system at Community Care Solutions is slightly different in that the Hub receives claims data from its health care partners (either from the regional health plan or the local independent medical practice that it contracts with) that the Hub uses to proactively identify high-risk individuals who could potentially benefit from the Hub’s services. The Hub then performs a home visit in which it conducts a needs assessment and identifies any health and social care service needs. In the case of Partners at Home, the payer refers patients to the Hub, and then the Hub contacts the referred patient to conduct an assessment in person or by phone. Partners at Home then makes referrals to CBOs in the network to address identified needs. There was only one Hub, WNYICC, in which CBOs were able to make cross referrals into the Hub (i.e., refer for other services offered by the Hub while receiving their referred services) rather than solely the other way around.

## Community Engagement and Governance

One of the potential benefits that the Hub model offers is to provide a structure through which communities can have input into health care priorities and the organization of care delivery. In many communities, health care payers and systems are distrusted and seen as large and distant organizations with their own financial and administrative priorities. In contrast, the CBOs that form the provider network for Hubs tend to be oriented toward immediate community needs. Specifically, communities of color and immigrant communities that have historically been underserved by health care institutions rely on CBOs to understand and respond to their health care and social service needs. By building a network of CBOs in a region, a Hub can provide a mechanism for local community organizations to have a role in determining how the social needs of community members are addressed.

There are a variety of mechanisms that Hubs can use to ensure that their policies reflect the priorities, goals, and culture of the communities they serve. The most formal mechanism is to have a community governance board, which can be used to formalize the relationship with the local community. In such a structure, community members and organizations can have a direct role setting policy and ensuring financial sustainability. A community governance board provides a formal structure for accountability to a community, but there are other, less formal ways that Hubs can give community members a “seat at the table.” For instance, advisory groups that meet regularly can offer CBOs a forum in which to discuss organizational policies and priorities.

Among the Hubs that we examined, none had a formal community governance board that was specific to the Hub, but all six had structured ways to incorporate community input into Hub policy. Three models of community input were identified, each with different strengths and limitations. First, three of the Hubs in our sample were formed by organizations that were already community-based social service agencies that served as nonprofit AAAs: VAAACares, Community Care Solutions, and DHAD. In two of these three cases, the Hub does not have a governing board that is separate from the governing board of the parent CBO (Bay Aging for VAAACares and DHAD for DHAD). In these cases, the parent CBO has a governing board that is designed to have representation from the community in which it is located. For example, the Bay Aging board consists of volunteers from the counties that the agency serves: ten appointed by their county’s board of supervisors and five chosen by citizens of the region. While the parent organization for the Hubs have boards with community representation, the Hubs cover larger areas than their parent organization and do not have boards that reflect the entire area of operations. In addition, the board of the parent CBO might not have the same interests as a board devoted exclusively to the Hub.

Although these Hubs do not have a community governing board, they all have advisory groups with diverse community representation that is focused specifically on the Hub operations. For example, VAAACares, which operates statewide in Virginia, has an advisory board that includes members of CBOs from across the state, state government officials, and policy experts with experience in the Virginia Medicaid system. These advisory groups provide input on community needs and on agency strategy and policy from an expert perspective. VAAACares has been considering giving this advisory board a more formal governance function but has not yet done so. DHAD, on the other hand, has community members who participate on its governing board in addition to its advisory group.

The second model is exemplified by both WNYICC, a Hub that was formed as a new independent organization by several AAAs in the western New York region, and Community Care Solutions. Without a single existing board to fall back on, WNYICC created a new governance board that consists of all the CBOs in the Hub network. Although this board includes community input through the CBOs, it does not include representatives from other segments of the community. The board meets regularly to discuss networking and policy issues, such as development of a response to the state’s plans for a section 1115 demonstration. According to Hub leadership, the goal for the organization is to have all member CBOs participate in board meetings and to participate on at least one board working group. However, according to the Hub discussants, the ability of CBOs to participate on the board varies widely; many CBOs do not have the capacity. Consequently, some organizations participate more in leadership and advisory roles than others. The leadership of the Hub recognizes that there is a balance between their expectation that CBOs participate in leadership and the burden that that responsibility places on them. CBOs do not face any restrictions on their participation in the network if they do not participate in the advisory group. In the case of Community Care Solutions, the Hub has a board of directors that is separate from its parent CBO (Southern Alabama Regional Council on Aging [SARCOA]). For input from community members, the Hub relies on its two partner AAAs (SARCOA and Central Alabama Aging Consortium [CAAC]). SARCOA and CAAC have advisory councils that consist of program participants, service providers, caregivers, and community members who give feedback to the AAA about their operations and provide information about the current and future needs of the elderly community. This information also informs Community Care Solutions’ work as a Hub.

Partners at Home exemplifies a third model, in which a Hub that has expanded across a large geographic area (in this case, the entire state of California), builds a standard mechanism for enabling the CBOs in each area to participate in Hub decisionmaking. In each county of California, Partners at Home creates an advisory board that consists of the CBOs in that county. The board meets regularly to discuss local issues, such as cost of living and pay, drive times, and other local factors that might differentially affect the CBOs in that county. This information is fed to the staff at the Hub to inform future contract negotiations. For example, CBOs in the Bay Area noted the high cost of living and need for additional payment for competitive salaries in the area. This information was used by the Hub to discuss payment and case rates with local payers. The organization of the advisory boards at the county level fits well within the Medicaid system in California because Medicaid managed care is also organized at the county level. These boards also act as a place in which network members can network and exchange best practices or share information informing their work in the county. Partners at Home noted that it is working on formalizing the structure of sharing information from the county level up for larger Hub awareness.

## Community, Health Care, and Government Partners

Relationship-building and creating partnerships with other CBOs, health care entities, and government agencies is one of the key roles that Hubs play in coordinating health and social care services.

### Community Partners

In several of the case studies, we found that Hubs were often entities that grew out of an original parent CBO, several of which were originally AAAs (Community Care Solutions, VAAACares, DHAD, WNYICC, Houston Health Department). As AAAs, these parent CBOs already offered clients in their region a wide variety of social services and had an existing network of CBOs that they could turn to for social services that were not directly provided by the parent CBO. The parent CBO and its existing network can then act as the initial set of partner CBOs for the Hub. In addition, as AAAs, there is a built-in network of other AAAs across the state that could be used to facilitate expansion into new geographic regions. One Hub highlighted that “the value in just sticking with the AAAs is we know each other. We have worked with each other for years. We openly share best practices with one another. We’re better together as an organization.” Because the needs of populations might vary by geographic region, Hubs also highlighted that the network of CBOs and the services they provide might differ by locality. This can also be related to the population density or rurality of an area: More-rural regions require patients or health coaches to travel farther to access or supply the needed services.

Finding and expanding the network of community partners was described as often happening through a “friends-of-friends” model, in which the Hub would add new partners that were recommended by or were similar to existing partners but that provided different services or were in different geographic areas. Hubs highlighted the importance of having discussions with potential new CBO partners about their capacity, data systems, ability to assess quality, cost of services, and other capabilities that are required to participate in the Hub network. At least one Hub, VAAACares, discussed making site visits to CBOs and vetting them before bringing new organizations into the network. Hubs also emphasized the importance of training new CBO partners to make sure their addition to the network is smooth and that it maintains necessary compliance standards.

Once the network is established, Hubs provide a variety of services to keep the CBOs engaged, strengthen links between member CBOs, and increase their capacity to provide services and participate in the network. Some of the Hubs have regular training sessions, focusing on such topics as IT, quality measurement, and business acumen. Regular meetings of network members are used to provide information on policy changes that are likely to affect CBOs and on opportunities for which they may have to develop new lines of service.

### Health Care Partners

Hubs’ partnerships with health care entities generally were with payers and providers of health care services. Payers included Medicare Advantage plans, Medicaid MCOs, and commercial insurance plans. In some cases, these relationships grew from initial contracts for the Hub to provide services and support only to the payer’s Medicare population to eventually— after the Hub demonstrated the value of the work it was doing for that population—cover all the health plan’s members.

Relationships with health care providers could be either formal contracted relationships or more informal partnerships. The contracted relationships were most often with hospitals and health systems that partner with the Hub to coordinate the health and social care of their high-risk patients. In one case, the Hub also contracted with an independent medical practice that was part of an Accountable Care Organization (ACO) to help coordinate care for its patients to meet the quality standards of the ACO. ^5^ Several case study participants pointed to their participation in CMS’ CCTP as being their first foray into the role of Hubs and including care coordination in their portfolio of work. Even when CCTP ended, the partnerships they had built with hospitals and health systems remained strong and continued into other contracts and programs managed by the Hub.

Relationships with skilled nursing facilities (SNFs), rehabilitation facilities, and primary care practices generally seemed more informal. At least one Hub described having open communication with SNFs and rehabilitation facilities so that it could plan for when clients might be discharged or return home, but that, for the most part, the facilities did care coordination and needs assessments themselves (rather than partnering with the Hub to provide those services) while the patient was at the facility.

None of the Hubs included in our case studies specifically discussed partnering with federally qualified health centers (FQHCs). Relationships with FQHCs are likely to exist but might be more informal and in need of more development. The Veterans Health Administration (VHA) was another health care entity that some of the Hubs we spoke with included as a partner.

Some of the Hubs we spoke with expressed struggling to establish contracting relationships with health care providers, suggesting that the providers would rather create their own internal program than to contract out to existing organizations like the Hub. Others also found it challenging to identify the right health providers to partner with, finding that many health care partners thought they could do the work themselves rather than contracting it out to the Hub.

### Government Partners

All the Hubs we spoke with work in some way with government partners, but these relationships were at times more informal than other partnerships. Hubs’ parent CBOs often have direct contracts for services with local and state governments; however, the relationships with the Hubs were limited to consultation and advice. At the federal level, CMS and ACL were both mentioned as government partners. As previously discussed, several Hubs got their start under CCTP and continued with other CMS programs, such as the Medicare Diabetes Prevention Program. In addition to setting standards and requirements for these programs, CMS has also acted as a payer for the work that Hubs and their network conduct. Additionally, parent CBOs of the Hub are often the lead entity for managing Medicaid waivers in their region. Hubs also discussed participating in various initiatives led by ACL and connecting with other Hubs through these initiatives. At the state and local level, several Hubs discussed having either formal partnerships or close relationships with their public health departments, city or county governments, state health departments, Medicaid agencies, and housing agencies.

All these partnerships at the local, state, and federal levels help to support the work that Hubs do by setting standards, initiating new programs, and providing access to subsidized services. However, the relationships between Hubs and government agencies were often not formalized, and there was no specific office or agency that the Hubs discussed as being their dominant regulatory agency.

The Hub that is being developed by the Houston Health Department is unique among our cases because the department is itself part of the city government. Also, in contrast with the other Hubs we examined, the AAA that is involved in development of the Hub sits within city government and not within a nonprofit organization. In this case, the relationship between the Hub and the government agency is stronger than in other Hubs we examined. However, there were also factors that, according to our discussants, were leading them to situate the Hub outside city government. On the one hand, the Houston Health Department has experience contracting with community-based social service providers across the city and ways of identifying areas with low geographic access to specific types of health resources. In this regard, the department is well situated to operate a Hub. On the other hand, being part of city government would make it very difficult to contract with health care payers and health care systems, which is the department’s primary goal in developing the Hub. As one of the discussants said, “We are a local government, and with local government comes a lot of the bureaucracy that you have to, you know, deal with.” For this reason, the emerging plan would situate the Hub outside the city government, in a nonprofit organization that has a long history of working with the department. That organization would be able to contract with health care entities more easily and take advantage of existing resources and relationships that the department has in building out its network of CBOs.

## Information-Sharing

To provide their services, Hubs need data systems and infrastructure in place to accept referrals, assign and track referrals, track service delivery, prepare reports for contract requirements, and transmit information to and from CBOs, payers, and health care providers. Health care payers and providers generally have sophisticated information systems to meet their operational and regulatory demands, while CBOs vary widely in their ability to report and share information. One of the goals of the Hubs is to reduce the barriers that CBOs face in coordinating care with health care entities.

Five of the six Hubs already have established data systems created over time and developed in conjunction with contracting relationships. The Houston Health Department has not started as a Hub yet but is already thinking through the type of system it will need and is currently discussing the use of an off-the-shelf commercial electronic health system with which the department has experience. The other five Hubs noted their ability to accept referrals and that they have a system to assign referrals to partner agencies. Often, the health care systems and CBO network systems are completely separate, requiring manual data entry to track a referral through the process of care.

Among Hubs with an existing information system, data is collected by care managers and Hub member agencies related to service delivery. Care managers input information related to assessments before enrollment and after completion of programs, and Hub members collect and transmit data relevant to payer contracts, including several process measures, such as service delivery status, time from referral to completion of service delivery, and patient or client satisfaction. This information is stored in the internal systems of the Hub and can be shared with other entities (e.g., payers) through structured reports. Reports can also be shared with partner CBOs. Partners at Home, for example, noted that it shares aggregated information about service delivery to partner agencies to show how well partners were performing.

Hubs that are further along in their development and infrastructure—WNYICC, Partners at Home, DHAD, and Community Care Solutions—have more-mature data systems for referral management and data-sharing. WNYICC, Partners at Home, and Community Care Solutions have both a single, streamlined internal data system that they use to track all the services provided by their partnered providers and a separate system for assigning and tracking referrals, while DHAD has multiple internal systems for data collection. Each considers its internal system to be a gold standard. These systems have been built over time and act as their sources of truth for service delivery and referral status. Because DHAD uses multiple internal systems, it discussed the challenges that come with combining and consolidating information across systems and programs. Even with internally integrated systems, Hubs can still struggle to create reports and share information outside the network because reporting requirements vary considerably from contract to contract.

One limitation noted by the more mature Hubs was the lack of integration and interoperability between the data from the health care system to the Hub and the data coming from the CBOs to the Hub. In some cases, such as DHAD, the Hub is using multiple systems to pull information into the organization, none of which are interoperable. Data extraction and transmission of data from the CBOs and from health care to the other is often done manually and with a large amount of labor. Data exchange is done through a secure file transfer portal (SFTP) because it contains protected health information (PHI). Community Care Solutions uses National Committee for Quality Assurance (NCQA) standards and minimum access standards to determine which users can see what information.^6^ WNYICC representatives noted that all CBOs are trained in proper data transmission protocols.

Some Hubs, such as VAAACares (which has a data system used internally to record care provided by CBO partners), emphasized the challenges of having separate data systems for reporting to each of their major stakeholders: the federal government, including reporting required by grants from ACL; state governments; and federal agencies on aging, transportation, and housing. Although Community Care Solutions has a single data system, it segments data such that information relevant only to its parent CBO (SARCOA) or to the Hub network are kept separate. Emerging Hubs, such as the Houston Health Department, are considering their data system and whether there needs to be different systems for the Hub entity and the service provider to ensure the proper firewalling of information between the service delivery and the Hub entity.

Partners at Home in particular noted issues with receiving outcomes data from its payer and provider partners. Similarly, VAAACares noted that it lacked access to information on utilization of acute care and costs of care. Payers and providers hold this data (i.e., claims and health status change), and Hubs are either not provided this data or have significant delays in receiving it. Without information on claims and other health outcomes, Hubs cannot determine the impact of their programs on health outcomes and must rely on process measures (e.g., whether referrals were sent on time) and internal program measures (e.g., assessment data on social needs before enrollment and after completion of the program) to judge efficacy. In addition, Hubs noted that each CBO might have its own system, or no system at all, so training CBOs on reporting often took time. Some CBOs do have experience reporting for grants, which was helpful in reporting data to the Hub. In contrast, health care organizations, payers, and providers alike have established capabilities for sending and receiving information based on the contracts negotiated with the Hubs. The information-sharing challenges with these entities is that they each have their own system that the Hubs need to learn to interact with. In addition, performance metrics for the contracts varied, adding to the reporting burden held by the Hub.

## Financing

Several common themes emerged across case studies regarding the financing of Hubs. First, the Hubs share a common sequence of financial development over time, starting with external sources of funding for their initial startup (such as grants from foundations or savings from their originating CBO), federal and other grant support during early development, and contract support via health care payers, such as Medicare, for their ongoing operations. In two cases, the initial startup funds came directly from within the CBOs that decided to invest in Hub development. In two other cases, startup funds were provided by foundation grants: one from a local foundation focused on the region’s health and one from a national foundation focused on improving the care for older adults. Notably, even organizations that had been AAAs required additional investments to develop into Hub organizations that work with a larger network of CBOs to address a wider variety of needs for a broader population.

External funding played an important developmental role in all the Hubs we examined. In some cases, a grant program preceded the organization becoming a Hub. For example, funding for the CCTP program enabled VAAACares to develop expertise and capacity in delivering hospital-to-home transition care and to develop a network of home care providers to implement the evidence-based model they were delivering. The skills and organizational infrastructure developed with federal support for that program enabled it to apply for further federal support through ACL to further build out its work as a Hub. Over time, grants came to play a smaller role in financing the Hubs and were replaced by contracts for services with health care payers and other health care entities. In several cases, contracts make up 100 percent of Hub revenue, while some other Hubs continue to receive a mix of contracts, grants, and donations from local philanthropies.

Second, most Hubs are financed using a fee-for-service model, but some alternative payment models are also being used. In the fee-for-service model, CBOs provide services and submit the claims to the Hub. The Hub submits the claims to the health care entity, receives the payment, and passes the payment to the CBO, taking a percentage for Hub operations. In the alternative payment models, which are being used by some of the Hubs we spoke with, including Partners at Home, Community Care Solutions, and DHAD, the Hub is paid a fixed amount per month or per intervention for each patient in its assigned caseload (either per person served or per member covered). In each of these cases, the Hub is the contracting partner and then subcontracts to other CBOs in the network for the services they provide. The Hub has the potential to make money if the costs are lower than the monthly payment, but is at risk of losing money if the costs are higher than the monthly payment. One Hub we spoke with has an additional performance-based risk component to its contract such that if it does not meet certain quality standards (e.g., on 30-day hospital readmission rates, patient satisfaction, or member engagement) its payment is reduced. One Hub that has only fee-for-service arrangements has been trying to convince the payers with which it contracts to switch to alternative models. The leader of this Hub told us, “I offered [the payers] to do a risk-based [payment], value-based [payment], you name it, and nobody wanted to.” This Hub leader believes that, given the chance, the Hub can demonstrate that the CBOs in its network are delivering high-quality care with positive outcomes on health and care utilization.

Third, braiding and blending of funds to meet the social needs of patients served by the Hubs was described as a common practice. Braiding and blending can be done by the Hub, but it was more commonly described at the CBO level, in which CBOs provide services to Hub clients that go beyond their contracted services, using funds from other sources. Consistently, the service for which external resources are used to supplement health care contracts is housing, in which CBOs receive support from federal and local government sources, as well as donations. There was also some concern that services that CBOs provide beyond those being paid for by the health care partner, which may be an expectation among some health care entities and policymakers, would serve as a form of subsidy for the health care partner that derives from volunteer efforts, donations, or other public funding sources. Additionally, Hubs discussed braiding and blending funding to cover the salaries of key staff during times of transition between contracts: for example, with CCTP ended and before new contracts with health care payers or providers officially began.

## Policy Issues

In discussions with Hubs, we asked about policies that, from the Hubs’ perspective, could improve their ability to be successful in their business activities and their coordination of health and social care services. The recommendations fall into three groups: (1) those related to information systems (including quality measurement and billing), (2) arrangements for paying for services provided or coordinated by the Hubs, and (3) other regulatory changes that would enable Hubs to be more effective and efficient.

### Information Systems

Discussants focused on methods for reducing the complexity of data collection and billing operations required by health care contracts, which remain challenging for Hubs and their CBO network partners. Some Hub staff suggested investing government funds into infrastructure for CBOs to enable data collection and quality measure reporting directly from service providers. In this vein, one discussant suggested investing in regionwide social care data platforms, which could provide a common platform for an entire network (enabling broader reach and capacity), standardize methods for referral tracking, and increase the transparency of network operations. However, discussants also noted that some population referral platforms are not able to document referral outcomes, care delivered by CBOs, or quality of CBO delivered care, all of which are essential for Hub operations. Currently, even within CBO networks, individual CBOs often use different information system platforms, which makes information-sharing challenging. Trying to get all CBOs within the network to use the same platform is challenging because switching platforms requires significant investments of staff time and funds. Some discussants also focused on the gap between information systems on the health care side and those on the CBO side, calling for guidelines to facilitate direct sharing of information. Guidelines for how to provide access to health information while also observing relevant laws regarding personal health information would, according to our discussant, address a major barrier to efficient functioning of the Hub. Another participating Hub suggested that a strategy similar to what was used in the health care sector to establish and reach meaningful use of EHR systems would be useful for CBOs and those providing long-term services and supports.^7^

Discussants also suggested that improvement in quality measurement using health information systems would also enhance their work. Standardized performance metrics would enable Hubs and their health care partners to better monitor and assess the care provided by CBOs. Measures that combine information from health and social care services sectors, such as measures of follow-up after a hospitalization, are of particular interest because they can be used to incentivize coordination across sectors. Improving the ability of Hubs to measure quality of care could also enable development of alternative payment models, as discussed below. Finally, one discussant emphasized that matching services provided by CBOs to fee-for-service billing codes is overly complicated. Better alignment of fee schedules with these services or alternative payment models would reduce the administrative burden on the Hub.

### Payment Arrangements

Discussants had two suggestions regarding the financing of Hubs. First, discussants suggested that federal or state government could provide startup funds to support network development. Startup funds could be used to address the IT issues discussed above and for other expenditures not covered by contracts, such as initial hiring and training of staff, organizing CBOs into a network, and coordinating Hub activities with AAAs and local government agencies. Second, some discussants from Hubs that operate on a fee-for-service basis would prefer to be financed through alternative payment models, in which they would be given more flexibility in providing services and be held accountable for quality and outcomes of care. Federal and state policies could encourage a shift from fee-for-service to alternative payment models in contracts with Hubs.

### Other Regulatory Changes

Discussants offered suggestions for regulatory changes that could improve their ability to operate effectively. One set of suggestions related to contracting between Hubs and health care entities. Discussants suggested that developing standards for contractual arrangements and workflow would provide consistency in their work across entities and across the regions or states in which they operate. Having a standard contract model would make the operations of the Hub more predictable and sustainable. One discussant suggested that guidelines should require quotas for a minimum number of referrals from the health care entity to the Hub, based on predicted level of need in the covered population, so that Hubs could more reliably predict their caseload size.

Another issue raised by one of the discussants relates to a proposed federal rule to require State Units on Aging to give prior approval of AAA contracts with nongovernment agencies. This rule would make it difficult (or impossible) for Hubs that sit within organizations that also have AAAs to contract with health care payers. Those contracts contain proprietary information about business practices that Hubs are not able to share or make public. This rule would effectively require the AAAs and the Hubs to form separate organizations—a process that, according to our discussant, would be expensive and wasteful.

## Summary

Table 3.2 summarizes the key information discussed above for the five active Hubs included as case studies.

Table 3.2 Summary of Community Care Hub Case Studies

Hub Characteristic | Community Care Solutions | DHAD | Partners at Home | VAAACares | WNYICC
Development | - Started by AAA; - Initial work as Hub under CCTP | - Started by AAA; - Initial work as Hub under CCTP | - Started as independent CBO, formed Hub for contracting across state | - Started by AAA | - Started by two AAAs
Geographic scope | - Sub-state region of Alabama | - Statewide in OH | - Statewide in CA | - Statewide in VA; some operations in other states | - Sub-state region of NY
Governance | - Board of directors specific to Hub; - Relies on advisory boards from CBOs in network | - Relies on parent CBO’s board of directors and advisory board | - County-level boards that report up to the organization | - Relies on parent CBO’s board of directors; - Has statewide advisory board | - Organization board of 11 voted on every three years with all CBOs as voting members; - Members encouraged to join one of six committees on the board
Client identification | - Proactive identification via claims data and hospitalization lists received from health care partners | - Daily census of potential clients received from health care partner; - Grand Rounds at hospitals | - Receives referrals from health care partners | - Receives referrals from health care partners | - Referrals through website, fax, health information exchange, or self-referral through another program
Services | - Health coaches conduct needs assessments and connect clients to social services | - Transitional care program that includes screening and assessment, medication reconciliation | - Care coordination services, including transitional care, personal care, homemaking, nonmedical respite, and meals | - Transitional care program, screening and assessment, care coordination | - Discharge meal delivery, coaching programs, falls prevention, diabetes programs
Community partners | - Parent CBO covers 11 counties; - Second AAA covers seven counties | - All AAAs in the state | - Identify partners in the counties based on contracts in the county; - Mostly focused on in-home care and care management and care coordination | - About 100 CBOs regularly and an additional 400 occasionally; - Includes most AAAs in state | - Partnered with 54 CBOs in 15 counties; - Includes eight AAAs and one CIL
Health care partners | - Contracts with regional health plan and local independent health care practice | - Contracts with regional health plan | - Medicare and Medicaid plans; - Health systems and hospitals | - Medicare and Medicaid plans; - Health systems and hospitals; - VHA | - Medicare Advantage and Medicaid plans, some regional and commercial plans
Government partners | - Alabama Department of Senior Services; - CMS | - Ohio Departments on Aging and of Medicaid; - CMS | - California Medicaid | - Advocacy with Virginia Department of Health; - Advisory group includes state official | - Two departments of health in the region
Information-sharing | - Developed own IT system; - CBO EHR not interoperable with health care partners | - Uses multiple systems, including a statewide health information exchange; - CBO EHR not interoperable with health care partners | - Commercial software for referral management, shares reported with payers and service providers; - CBO EHR not interoperable with health care partners | - Developed EHR for CBO network; - CBO EHR not interoperable with health care partners | - Uses a centralized electronic client record that was built to track and manage referrals, document program delivery, and submit claims; - Not interoperable with health care partners
Financing | - Per-member per-month payment for contracts with health care entities; - Blending and braiding funding from other sources | - Per-intervention payment with risk component based on quality goals for contract | - Case rate payments from contracts that sustain operations; - Grants for startup funding | - Fee-for-service contracts; - Blending and braiding funding from other sources | - Payments dictated by contracts with payers; - Blending and braiding funding from other sources

NOTES: CIL = Center for Independent Living. The Houston Health Department Hub has not been included in this table because that Hub is still in development.

3 AAAs are state-designated agencies that coordinate and offer services to address the needs of older adults in specific geographic regions and allow them to remain in their homes. AAAs can be public, private, nonprofit, or quasi-governmental organizations (Administration for Community Living, 2023). These organizations work to help older adults remain in their homes by helping to coordinate their care and services. Many AAAs also run Aging and Disability Resource Centers, which are part of the No Wrong Door model to streamline access to long-term services and supports for key populations, including older adults, people with disabilities, and their families (Administration for Community Living, 2017)a.

4 CCTP was launched by CMS in 2012 and aimed to improve quality and patient experience and reduce costs associated with care transitions. The five-year program provided funding to CBOs to establish partnerships with hospitals and other health care providers to improve high-risk Medicare beneficiaries’ care transitions. Participants paired existing care transition models with additional social services and supports to reduce readmissions (Ruiz et al., 2017).

5 ACOs are groups of health care providers that voluntarily come together to coordinate care. ACOs that are successful in delivering high-quality care and producing cost savings for Medicare share in these savings. In some cases, ACOs also take on downside risk in which they also share in any additional costs that Medicare takes on (should there be any). Medicare beneficiaries are assigned to an ACO based on their use of services. This assignment determines which patients are included in evaluations of the ACO in terms of savings and costs.

6 NCQA establishes standards and accreditations for organizations working across the health care system, including organizations like Hubs. These standards can include an accreditation for case management or long term and social support services.

7 In the 2010s, CMS established a meaningful use program in which it provided incentives to health care entities to accelerate the adoption of EHRs that met certain requirements.