# Chapter 2 Landscape of Health and Social Care Coordination

In FY 2022, ASPE engaged RAND to identify best practices in implementing and operating health and social care service care coordination efforts at the local level. In this first stage, we conducted an environmental scan that included a literature review and semistructured discussions with key informants. The literature review focused on the peer-reviewed and grey literature related to approaches to coordination of health and social care services. The key informant discussions with representatives from backbone organizations and academic experts focused on understanding the structure and finances of backbone organizations, their operations, and policy-related factors that help or hinder their operation. In this chapter, we summarize key findings from the first phase of this work. In addition, we focus on how the prior phase informed the strategy for sampling Hubs and developing the discussion protocols for the second phase of the study.

## Literature Review

### Methods

The literature review that we conducted as part of the FY 2022 environmental scan provides a high-level summary of the academic and grey literature about community-based approaches to coordinating health and social care services. To conduct the literature review, we developed a narrowly scoped set of search terms, which included care coordination, case management, managed care, social service, and integrated care. A set of Medical Subject Headings (MeSH) terms, which included social work, social support, integrated delivery of health care, and community health services, were also employed. The search terms also included terms related to specific initiatives identified by the project team, including Pathways Community HUB, Accountable Health Communities, and Medicaid section 1115 demonstrations. The approach was refined and implemented by a RAND research librarian using PubMed. The results were limited to articles in English published within the past five years. The search was tested using relevant articles suggested by the project team. The relevance of the initiatives was determined based on ASPE feedback. The final sample of 115 articles were identified after a full text review of 272 articles identified as relevant from a title and abstract screen of 1,172 articles produced by the initial search. From the review, we abstracted the following information: geographic context, coordination model, health services offered, social services offered, coordinating entity, entities involved, populations covered, health conditions covered, funding, planning or governance model, data-sharing approach, and other characteristics.

### Findings

Our review of the literature identified seven categories of health and social care service coordination initiatives that were highly relevant given our inclusion and exclusion criteria and through consultation with ASPE: (1) Accountable Communities for Health; (2) Medicaid Accountable Care Organizations; (3) Community Integrated Health Networks; (4) shared stewardship for wellbeing, equity, and racial justice; (5) Medicaid care coordination for whole-person care; (6) maternal care coordination; and (7) Pathways Community HUB.

While all the models examined have backbone organizations that serve as a centralized point of contact for identifying individuals in need of care and sharing information to facilitate coordination, the models are distinguished by being based within the government, health system, or community. An example of a government-based backbone organization is the Anne Arundel County Partnership for Children, Youth and Families in Maryland. This organization is a county-based system of local management boards that work with community organizations, local government agencies, and health care systems to identify and address local health care needs (Rozansky, 2011). Other government-based backbone organizations include Hennepin Health, in which a county government serves as an Accountable Care Organization for its Medicaid population. The second base of backbone organizations is the health system that links health care services with a network of community-based social service agencies. Examples of health system–based backbone organizations include some of the Accountable Health Communities (AHCs) created through a CMS demonstration project (Renaud et al., 2023). AHCs were designed with “bridge organizations” that provided the backbone organization functions. Another example of a health system–based backbone organization is the New York State Health Home model, in which Medicaid payers serve as backbone organizations, connecting patients with complex medical needs to social services through case management organizations (Mayer et al., 2021; Scharf et al., 2014). The final base of backbone organizations is the community, independent from both governmental and health system organizations. Community-based backbone organizations include nonprofit organizations that provide a centralized administrative and operational interface between health care institutions and a network of CBOs that provide social services. Examples include AgeSpan in Massachusetts, which developed out of a local Area Agency on Aging (AAA) serving an elderly population and now has expanded to provide services to individuals with disabilities. Another example of a community-based backbone organization is Partners in Care, which started in 1997 in Southern California but has expanded through contracts with MCOs to provide access to networks of CBOs across California.

These backbone organizations differ in important ways that affect their function and potential impact, such as their engagement with the health care payers. According to the literature review, backbone organizations based in governments, health systems, or communities each share characteristics in the following areas.

#### Planning and Governance

The initiatives were typically governed by independent purpose-built nonprofit organizations, leadership coalitions consisting of representatives from participating organizations, and/or formal contractual agreements between participating organizations. The individual governing organizations included health care providers or payers (e.g., health systems or federally qualified health centers, Medicaid managed care plans), government agencies (e.g., county departments of health, social service agencies), and community-based stakeholders (e.g., local social service organizations or patient representatives). The underlying mandate for initiatives varied, with some reflecting federal policies (e.g., Veteran Affairs’ [VA] national maternity care policy, Medicaid section 1115 demonstration, or a CMS Innovation Center pilot) and others reflecting state or local priorities.

#### Funding

Funding arrangements for coordination tasks and care varied between projects, but most initiatives relied on federal funding from health care payers (such as Medicare and Medicaid) transmitted to the community-based backbone organizations and then distributed to CBOs. However, because social services represent a limited set of Healthcare Common Procedure Coding System (HCPCS) and Current Procedural Terminology (CPT) codes and payment mechanisms, these funding sources are inherently limited. Consequently, community-based backbone organizations supplement these funding sources with combined contributions from local health systems, state or county health agencies, and other philanthropic partners. Detailed information on funding was not available for most of the organizations described in the literature.

#### Data Infrastructure

In most instances, data were managed or housed by the lead coordinating organization. With few exceptions (e.g., Pathways Community HUB), the precise configuration of data-sharing agreements and infrastructure was not captured in the literature. Data elements included electronic health records (EHRs), service referrals, social service encounter records, SDOH data, and other data from CBOs and were typically accessible by social service providers, health care providers, and initiative coordinators.

#### Scope and Populations Covered

Most highly relevant initiatives were implemented at the city, county, or regional level, often in partnership with a large health system or large health agency. The populations covered by these initiatives include high health care utilizers, older adults, pregnant people, veterans, and people experiencing poverty or homelessness. Although the conditions that are covered varied by initiative, some conditions of focus included pregnancy, severe mental illness, substance use disorder, disability, and other chronic conditions.

#### Health and Social Care Services Coordinated

Highly relevant initiatives coordinated a variety of health care services, including primary care, behavioral health care, dental care, obstetric or postpartum care, health education, family planning, breastfeeding support, and screening. The social services that are often coordinated by strongly aligned initiatives include housing support, nutrition support, public assistance enrollment support, substance use treatment, smoking or alcohol cessation, and interpersonal and intimate partner violence services.

## Key Informant Discussions

### Methods

The second component of the FY 2022 environmental scan conducted was a series of semistructured discussions with key informants drawn from a variety of organizations that coordinate health and social care services and with academic experts who study how these organizations work. Using the results of the literature review and leveraging ASPE contacts, we identified a list of potential key informants. Priority was given to individuals associated with initiatives that engaged in a broad scope of coordinating efforts and/or organizations that served a large or scalable population. As a result, 14 individuals/groups were identified, invited, and accepted participation in scheduled, semistructured discussions, as described in Table 2.1.

To facilitate the semistructured discussions with key informants, we developed a discussion guide drawing on the literature review and the interests specified by ASPE. We identified areas that required further clarification or that were missing from the published literature. Additionally, the discussion guide incorporates ASPE interests in (1) contextual factors, (2) planning and governance models, and (3) structural details (e.g., leadership, tracking). The discussion guide was designed to include probes and prompts for more discussion of the ideas raised by the key informants. Appendix A contains the FY 2022 discussion guide.

Table 2.1 Key Informants

Name | Title(s) | Affiliation(s) | Type of Organization
Pam Brown, PhD | Executive Director | Anne Arundel County Partnership for Children, Youth and Families | Health and social care service coordinating initiative
Jeff Levi, PhD | Director | George Washington Funders Forum on Accountable Health | Academic/research institute
Bruce Goldberg, MD | Director | Oregon Accountable Health Communities | Health and social care service coordinating initiative
Robyn Golden, LCSW, and Bonnie Ewald | Associate Vice President, Department Chair; Associate Director | Rush University Medical Center, Center for Health and Social Care Integration | Health services
Jennifer Raymond, JD, MBA, and Joan Hatem Roy, LICSW | Chief Strategy Officer; Chief Executive Officer | AgeSpan | Health and social care service coordinating initiative
Len Nichols, PhD | Director, Center for Health Policy Research and Ethics | Urban Institute | Academic/research institute
Toyin Ajayi, MD, MPhil | Co-founder and Chief Executive Officer, SIREN National Program Leadership | Cityblock Health, SIREN | Health and social care service coordinating initiative
Kate Diaz Vickery, MD, MSc | Physician | Hennepin Health | Health plan and accountable care organization
Connie Benton Wolfe, MA | President and Chief Executive Officer | Aging and In-Home Services of Northeast Indiana, Inc., Ground Game Health | Health and social care service coordinating initiative
Erica Coletti, MBA, and Michele Horan | Chief Executive Officer; Chief Operating Officer | Healthy Alliance | Health and social care service coordinating initiative
Stuart Butler, PhD | Senior Fellow in Economic Studies | Brookings Institution | Academic/research institute
June Simmons, MSW, and Ester Sefilyan | President and Chief Executive Officer; Vice President of Network Services | Partners in Care Foundation | Health and social care service coordinating initiative
Rishi Manchanda, MD, MPH and Sadena Thevarajah, JD | Founder and President, SIREN National Program Leadership; Managing Director | HealthBegins, SIREN | Health and social care service coordinating initiative
Charlene Wong, MD, MSHP | Executive Director | North Carolina Integrated Care for Kids Model | Health and social care service coordinating initiative

### Key Themes

Discussions with key informants took place in September 2022, and several key themes emerged.

#### What Makes a Good Backbone Organization?

Throughout the key informant conversations, participants discussed the qualities that make an organization a good backbone organization, contrasting different types of backbone organizations. The primary advantage of having a CBO serve as a backbone organization, as opposed to a health care or governmental organization, was described as deriving from the trust that CBOs can establish with social service providers on the one hand and health care institutions on the other. The CBO serving as a backbone organization must have the qualities that each type of stakeholder regards as crucial for collaboration. For the social services organizations, CBOs provide a fair and financially disinterested mediator to facilitate negotiation and contracting with health care providers. As one discussant emphasized, social service organizations want a partner that shares their values in serving the community. Developing trust with health care institutions that backbone organizations work with (including public payers, such as Medicare Advantage plans or Medicaid MCOs; commercial insurance companies; health care systems; and hospitals) requires that the backbone organization have a high level of sophistication with respect to managing contracts, collecting and sharing information using standardized formats, and assessing the quantity and quality of services that are provided. One discussant highlighted this tension by saying that the best backbone organizations are those that grow organically from within the community, but for funders to feel safe investing in a backbone organization, they need to see certain credentials.

Backbone organizations aim to address the misalignment of the health and social care services sectors by providing a single point of contact between these sectors. From the health sector perspective, the backbone organization offers a single organization with which they can interact that can provide access to an entire network of social services providers rather than having to manage relationships with each provider individually. Health care organizations can thus offer social services to patients who are likely to benefit from the services through reduced acute care utilization and improved quality of life without taking on the task of directly providing the services or contracting directly and separately with many CBOs. Moreover, the backbone organization can be held accountable for reporting on service provision and quality measures in ways that meet the contractual obligations of health care organizations, while many CBOs would not be prepared for the required reporting.

From the CBO perspective, the backbone organization provides access to health services for the people they serve and a predictable and sustainable source of referrals and revenues. Through the backbone organization, the CBOs have the potential to access health care resources without having to negotiate on an individual basis with much larger institutions or make large investments in their own administrative capacity. Backbone organizations can also take on administrative functions, such as billing, that would stretch the capabilities of CBOs on their own. Importantly, for both health care entities and CBOs, the backbone organization is a “trusted broker,” an independent organization without a competitive financial interest (Nichols and Taylor, 2018). CBOs can trust that the backbone organization will represent their interests in negotiating prices and other contractual issues with health care entities.

Through coordination of health and social care services, backbone organizations have the potential to improve a broad variety of health outcomes. For patients with complex medical conditions, better access to social services can enable them to live independently in their homes and communities, avoiding health crises, visits to emergency departments, and hospitalizations.

#### Non-Health Care Providers Need a True Seat at the Table

Discussants also emphasized the need to address the enormous power differential between social service organizations and health care providers and payers in the governance and practice of backbone organizations. Without direct support for social service organizations, including technical assistance in many cases, the non–health care organizations could be dominated by health care interests and fail to achieve coordination with CBOs. One discussant emphasized the importance of building a new sort of ecosystem of health, centered on the involvement of social service organizations as true partners. The involvement of social service organizations, according to discussants, should include an equal voice in how priorities are set and how infrastructure for care coordination, such as EHR systems, are designed and implemented.

#### Data Collection, Sharing, and Standardization

The role of data collection and sharing was also a key consideration discussed by informants. Information transfer can be challenging (particularly across health and social care service providers) because each partner uses different systems, and there are specific requirements and data safeguarding that must be maintained. One discussant underscored that, because billing, workflows, and processes are not currently standardized across health and social care service providers, building stronger data systems with better integration would allow for improved coordination and delivery of services. Data standardization was also an important theme from the discussions, with informants highlighting how the lack of standardization can make it challenging to merge data systems, understand disparities, and evaluate programs. One discussant captured this issue when describing a standardized questionnaire that they created to purposely align with Medicaid, as opposed to other core measures that often do not align with federal measures.

#### Funding Challenges and Sustainability

Discussion participants brought up challenges that health and social care service coordination initiatives face in terms of finding sustainable, sufficient funding. Generally, CBOs receive funding via health care payers, essentially compensating the CBOs for the reduction in health care costs produced by their services. However, informants brought up the limitations around what CBOs and social service providers can bill to payers, such as Medicare (including the type of providers who are eligible to bill Medicare); the lopsided funding for health care services over social services; and the importance of braiding and blending funding across a variety of sources. Several discussants mentioned that social workers and community health workers do not have access to many of the HCPCS and CPT codes and payment mechanisms through value-based payment models that physicians and other providers can access, despite being on the front lines of coordinating health and social care services. There was also a call for additional and clear guidance for CBOs on any restrictions on how they are allowed to use federal funding when addressing community needs. As one informant emphasized, fear of differing interpretations of these guidelines by auditors might be a barrier to entering these initiatives for some health care organizations. The challenges surrounding access to consistent and adequate funding was a key consideration for both the initiation and continuation of these coordination initiatives.

#### Role of Federal, State, and Local Governments

The role that the government plays was also discussed by informants as an important part of how successful initiatives can be. Several informants stressed the important role that section 1115 demonstrations have played in allowing more flexible use of Medicaid funding. Participants underscored how government support, through policies like the Medicaid waivers, signals to potential network participants and the larger community that these initiatives are important. Having buy-in from federal, state, and local policymakers gives credence to these efforts and can foster a policy environment that leads to additional support for backbone organizations, both financially and administratively. As one discussant explained, once there was leadership support from the state, “it was really not hard to get people on board” with their effort. Social service organizations in particular “had been trying to find a way in” to integrating with health care, and the promise of integrated care delivery, data, and a novel payment model was more than enough to bring people to the table.

#### Potential for Telehealth

Telehealth’s increasing role in the provision of health care and social services was another recurrent theme in discussions. Under the COVD-19 public health emergency, regulations governing how and when telehealth services could be used were relaxed. Allowing for health and social care to be provided outside of in-person visits can increase access to screening and services. As one discussant indicated, the ability to use phone calls to screen for SDOH and arrange for direct services was a benefit of relaxed regulations during the COVID-19 pandemic, and although much work needs to be done in-person, the option to supplement work with phone calls and texting could increase access for people who face transportation barriers and other challenges. Informants pushed for continuation of the recent telehealth flexibilities so that remote access to care can be provided to those who could benefit from it.

## Phase Two

The results of the environmental scan informed the second phase of the work and led to the focus on one particular model for coordinating health and social care services—Community Care Hubs (or Hubs)—in FY 2023. The environmental scan also informed the selection of case study Hubs based on important contextual characteristics, such as urbanicity, organization size and coverage area, connection to health care system, and the larger area’s health care landscape.