# Chapter 1 Community Care Hubs and Integration of Health and Social Care Services

As part of its strategy for addressing the impact of social determinants of health (SDOH), the U.S. Department of Health and Human Services (HHS) is prioritizing the coordination of health and social care services (De Lew and Sommers, 2022). The approach recognizes that health care, narrowly conceived, is limited by its focus on treatment of specific medical conditions, while the incidence and prognosis of most medical conditions is powerfully influenced by the social conditions in which people live and work (Gómez et al., 2021). Historically, health care institutions have not had the capabilities or resources to address health-related social needs (HRSNs), such as access to safe and stable housing, nutritional diets, and transportation. Integration of health care institutions with social service agencies, which directly address HRSNs, is seen by HHS as a critical approach to improving population health, particularly for low-income and disadvantaged populations, including Medicare and Medicaid beneficiaries (Chappel et al., 2022)..

The coordination of health and social care services faces numerous challenges (National Academies of Sciences, 2019). The health care industry is increasingly characterized by large-scale payers and delivery systems that operate in multiple states or across large regions. These entities operate in a highly complex regulatory environment using sophisticated administrative systems and information technology (IT) to manage clinical care and business processes. Relative to organizations in the health care industry, the organizations that provide social services tend to be small, community-based organizations (CBOs) oriented toward service to their local area and responsive to its needs. These organizations frequently lack the technological, administrative, and financial means to conduct business in the health sector. Moreover, the social services sector in any given geographic area tends to be fragmented, populated by multiple organizations with diverse constituencies, capabilities, missions, and resources, which challenges health care organizations that require standardized service provision at scale.

Given these challenges, there is great interest in innovative institutional arrangements that can bridge the gap between health and social care services, aligning across organizations to facilitate coordination of care for individual patients. For instance, the Centers for Medicare and Medicaid Services (CMS), through section 1115 demonstrations, Medicare Advantage supplemental benefits, the Merit-Based Incentive Payment System, and other programs, is promoting routine identification of HRSNs in health care settings and, in some cases, providing for coverage for services to address transportation, food insecurity, and housing issues. The Administration for Community Living (ACL) and Centers for Disease Control and Prevention (CDC) are using grant programs to support development of infrastructure to connect health and social care sectors. ACL will be funding a new Center of Excellence to Align Health and Social Care with up to 20 competitive subawards. To help assess SDOH at a population level, the CDC has provided states with an SDOH module for the Behavioral Risk Factor Surveillance System. The Office of the National Coordinator for Health Information Technology (ONC) is supporting SDOH data standardization, such as the United States Core Data for Interoperability, to facilitate effective cross-sector referrals and person-centered care.

## Investigating Backbone Organizations

One of the organizational strategies for bridging health and social care that has developed in recent years involves the use of a backbone organization, an independent organization that provides the infrastructure to connect and facilitate interactions between health care entities and social care providers in the community. In the first phase of this project, the Office of the Assistant Secretary for Planning and Evaluation (ASPE) contracted with the RAND Corporation to conduct an environmental scan to identify best practices in implementing and operating health and social care service coordination efforts at the local level. The environmental scan consisted of a literature review and semistructured discussions with key informant practitioners, policymakers, and experts.

The literature review of academic and grey literature provided a high-level summary of initiatives that coordinate health and social care services. Within the literature review, seven categories of highly relevant health care and social service coordination initiatives were identified in consultation with ASPE: (1) Accountable Communities for Health; (2) Medicaid Accountable Care Organizations; (3) Community Integrated Health Networks; (4) shared stewardship for wellbeing, equity, and racial justice; (5) Medicaid care coordination for whole-person care; (6) maternal care coordination; and (7) Pathways Community HUB. Reviewing these categories of health and social care service coordination initiatives revealed a variety of models for backbone organizations based within the health system, government, or community and shared characteristics in the areas of planning and governance, funding, data infrastructure, and scope and populations covered.

Informed by the literature review, we then conducted a series of semistructured discussions with 14 key informants drawn from backbone organizations and academic experts who study how these organizations work. From these key informant discussions, several key themes emerged. One key distinction that emerged from the environmental scan was where the backbone organization was based: government, health system, or community. Key informants described that it was advantageous to have a CBO that has the trust of social service providers serve as the backbone organization instead of an organization based in the government or a health system. Key informants also emphasized the need for CBOs to have an equal voice in the network to address the power differential with health systems. The next key considerations discussed by informants were the importance of data collection, sharing, and standardization, which are key for coordination and delivery of services. Additionally, key informants described the challenges that backbone organizations face in finding sustainable, sufficient funding. Typically, funding comes from health care payers, compensating for the reduction in health care costs produced by the social services. But because social services represent a limited set of payment mechanisms, backbone organizations are forced to braid and blend these funding across a variety of sources. Relatedly, key informants discussed the role of governments in successful backbone organizations. For instance, several informants stressed the important role that section 1115 demonstrations have played in allowing more flexible use of Medicaid funding. The final key theme from the key informant discussions was the potential for telehealth. Allowing for health and social care to be provided outside in-person visits can increase access to screening and services, as evidenced by the relaxed regulations on telehealth services implemented during the COVID-19 public health emergency.

Overall, the results of the environmental scan describe a variety of models for backbone organizations that coordinate health and social care services and the common issues that affect their implementation and success. The second phase of the project built on the results of the environmental scan to explore select backbone organizations in greater depth through six case studies. Following from the results of the environmental scan, the case studies focused on backbone organizations based in the community that coordinate health and social care services, otherwise known as Community Care Hubs.

## Case Studies of Community Care Hubs

In the second phase of this project, we conducted a series of case studies of one type of community-based backbone organization of particular interest to ASPE, known as a Community Care Hub, or Hub. Hubs are nonprofit organizations that provide a centralized administrative and operational interface between health care institutions and a network of CBOs that provide social services. As a centralized administrative and operational interface, Hubs offer a promising strategy for coordinating health care institutions and CBOs that provide social services (Chappel et al., 2022; Dutton et al., 2022). The health care institutions that Hubs work with include public payers, such as Medicare Advantage plans or Medicaid managed care organizations (MCOs), commercial insurance companies, health care systems, and hospitals. The CBOs tend to be a diverse set of organizations, each of which that operates within a limited geographic area. Collectively, the network of CBOs provides a wide variety of services, including housing, in-home meal services, and transportation.

Hubs aim to address the misalignment of the health and social care services sectors by providing a single point of contact between the health and social care services sectors. From the health system perspective, the Hub offers a single agency that can provide access to an entire network of CBOs rather than having to manage relationships with each individually. Health systems can thus offer social services to patients who are likely to benefit from them—through reduced acute care utilization and improved quality of life—without taking on the task of directly providing the services or contracting directly and separately with many CBOs. Moreover, the Hub can be held accountable for reporting on service provision and quality measures (e.g., Were the patient’s social needs met?) in ways that meet the contractual obligations of health systems. The reporting process is thus much simpler than it would be if the health care systems were to work individually with each CBO.

From the CBO perspective, the Hub provides a larger and more predictable source of referrals than the CBO would have if it relied exclusively on community-generated referrals. The health care partners are systematically identifying individuals with needs for community-based services and referring them to the Hubs. The Hub also provides a more sustainable source of financing, given that many CBOs rely heavily on grant funding. Through the Hub, the CBOs establish working relationships with health care entities without having to negotiate on an individual basis with much larger institutions or make large investments in their own administrative capacity. Hubs can also take on administrative functions, such as billing, that would stretch the capabilities of CBOs on their own. Importantly, for both health care entities and CBOs, the Hub is a “trusted broker,” an independent organization without a competitive financial interest (Nichols and Taylor, 2018).

By facilitating access to a network of social care providers for patients with HRSNs, Hubs have the potential to improve a broad variety of health outcomes. For patients with complex medical conditions, better access to social care services can enable them to live comfortably in their homes and communities, avoiding health crises, visits to emergency departments, and hospitalizations. Community-based social service providers are also in a position to conduct comprehensive assessments of individuals’ needs in their home context, giving them the ability to identify and address needs that would not come to the attention of medical providers. These assessments also enable a more tailored approach to addressing an individual’s needs, including accounting for the specific barriers that individuals face, such as lack of access to healthy foods or transportation to medical appointments.

To examine how Hubs are currently operating across the United States, we conducted a series of six case studies. The Hubs were selected with input from federal partners from a list of Hubs currently participating in a national learning community supported by ACL. Hubs were selected to include different regions of the country, sizes, and stages of organizational development. One of the selected Hubs is still in its planning stage, two cover specific regions within their states, and three have expanded to include whole states or operate in multiple states.

The case studies were conducted using a combination of document review and semistructured discussions with the leadership of each Hub. Multiple discussions were held with each of the six Hubs. The discussions covered the Hubs’ (1) governance and organizational structure; (2) partners in CBOs, health care, and government; (3) IT and financing strategies; and (4) local policy context. In each of these domains, we asked discussants to describe challenges that they face and key policy issues at the local, state, and federal levels that have helped or hindered their development to date. Information from the document reviews and discussions were synthesized into case study descriptions for each of the Hubs. The six case studies were then compared to highlight similarities and contrasts.

## Organization of the Report

In Chapter 2, we present the results from the first phase of the study that examined backbone organizations, conducted during fiscal year (FY) 2022. Results of the case studies conducted during FY 2023 are reported in Chapter 3. In the concluding chapter, we highlight key takeaways from the case studies and emerging policy issues. Our discussion guides from the FY 2022 and FY 2023 projects are presented in Appendixes A and B. Summaries of the case study Hubs are presented in Appendix C.