# Appendix C Detailed Case Study Summaries

## VAAACares

Virginia Area Agencies on Aging—Caring for the Commonwealth (VAAACares) is a Hub operating statewide in Virginia. The Hub grew out of a nonprofit AAA known as Bay Aging, which has operated since 1978 in the largely rural Middle Peninsula and Northern Neck region of the state. The origins of VAAACares date to 2012, when Bay Aging received funding from the CMS Innovation Center’s CCTP (Vesley-Massey, 2019). The CCTP provided support services for Medicare beneficiaries during their transition from hospital or nursing homes to their own homes, with the goal of avoiding readmissions. In 2013, Bay Aging expanded the CCTP program to include five health systems, 69 skilled nursing facilities, and four AAAs covering 20 percent of the state. The new program, called the Eastern Virginia Care Transitions Partnership (EVCTP), followed the Care Transitions Intervention model, in which coaches provide in-home assessments and care coordination in addition to fall-prevention and chronic disease self-management counseling using motivational interviewing techniques. Building on the experience and infrastructure of the EVCTP, Bay Aging led an expansion of the service network by partnering with AAAs across the state and forming VAAACares. The Hub remains headquartered at Bay Aging but now covers the entire state and has begun to work outside Virginia, providing financial management contracts and hub-and-spoke model networks in other states.

### Community Governance

VAAACares does not have a separate governance board from Bay Aging. The board of directors for Bay Aging is composed of elected public officials, representatives of low-income persons in the areas served, and members of businesses or organizations in the community. VAAACares is currently considering developing its own community governance board. The Hub has an advisory group, which includes diverse community members and has a cochair in the governor’s office; the Hub is thinking of formalizing this group into an official advisory or governance body for the organization. VAAACares holds stakeholder meetings for its CBO network, which are attended by about 150 organizations.

### Relationships with Community-Based Provider Organizations

VAAACares’s parent organization, Bay Aging, is a AAA, which has a history of direct service provision and contracting with local provider agencies. The Hub maintains these relationships locally while developing new relationships with provider agencies in other areas in which it operates. In some cases, relationships with provider agencies are mediated through other local AAAs; in other cases, the Hub connects directly with community providers. Relationships with provider organizations are established on a one-by-one basis, starting with discussions of the CBO’s capacity, data systems, ability to assess quality and cost of services, and other capabilities that are required to participate in the Hub network. After initial discussions, VAAACares staff often make site visits to CBOs to see the facilities and their operations in person. As one discussant described this process, “It’s just like dating. Do we have anything in common? What are your interests?” The CBOs are vetted formally using readiness assessments, similar to those used by payers to assess Bay Aging. VAAACares also provides training in business acumen to CBO provider organizations that is designed to strengthen these organizations’ administrative capabilities so that they can continue to operate independently, without being absorbed into a larger organization that would be less tied to its local community. The Hub refers to about 100 CBOs on a daily basis and can draw on an additional group of about 400 organizations for more occasional referrals.

### Health Care Partners

VAAACares has contracts with Medicare and Medicaid managed care plans, health systems and hospitals, and the VHA. The contracts generally involve serving as a single contracting entity for a network of CBOs to provide post-acute care for designated lists of payer or health system beneficiaries or patients. The services are generally financed on a fee-for-service basis, with a small percentage of billing allocated to VAAACares to support its role as the Hub. According to the Hub leadership, the Hub has advocated for value-based payments, in which it would be held accountable for performance on quality metrics, but the payers have not agreed to these arrangements.

### Government Partners

VAAACares interacts with the Virginia Department of Health (VDoH) in activities related to certification and training of staff, which the department regulates as requirements for reimbursement. The Hub has had the health coaches be trained and certified as community health workers. From the Hub’s perspective, the certification enhances the capacity of the coaches and enables the Hub to provide a broader variety of services, for which it also provides training, such as evidence-based behavioral health and fall prevention programs. VAAACares also routinely works closely with the state secretary for health and human resources on issues, such as certification and health information exchanges. However, the VDoH is not aligned with the goals of the Hub in all respects. For instance, VDoH has contracted with a for-profit company to develop referral software using a commercial platform, which does not fit well with the Hub model because it simply announces referrals without tracking subsequent service provision and quality of care.

### Hub Services and Operations

The primary focus of VAAACares, in line with its origins in the CCTP, is on care coordination and navigation linking acute care with home-based care. Some of the programs continue to use a coaching model, in which a coach meets with a beneficiary in the hospital prior to discharge, assesses their home-based health care needs, and follows up with the beneficiary post-discharge to directly assess the at-home conditions and arrange for services to address ongoing needs. In addition to the care transitions services, VAAACares also provides access to home and community-based care coordination to address transportation, food insecurity, housing, social isolation, chronic disease, and fall prevention; comprehensive needs assessments for MCO beneficiaries; and home and community-based models of care for chronic disease self-management, depression and anxiety, mental health first aid, motivational interviewing, and fall prevention.

Informants emphasized that the most difficult HRSN to address is housing: “We can’t make promises on housing.” The Hub can connect beneficiaries to housing support services, but these services tend to have long wait times and not result in immediate housing placement. The difficulty in addressing housing insecurity is simply the high cost of housing: “It is so expensive that MCO’s do not want to reimburse us what it would cost to house someone.”

Individuals access Hub services exclusively through referrals from the health system or payer that they contract with; there are no self-referrals. The Hub receives files with names and contact information from the health system or payer. The Hub then sorts the contacts and fields them out to the appropriate CBOs. If the contract is for coaching services, the CBO will select the coach, who will meet with the beneficiary in the hospital and begin preparing for the move home. In other cases, depending on the contract terms, an assessment may be made over the phone, or the referral may come in after an assessment has been made. Some contracts are for care coordination for beneficiaries who are already in the community. For these contracts, the Hub will receive names and contact info from the provider and pass them to a CBO to make cold calls; a CBO might make 50 to 70 calls in a day, resulting in new connections with ten beneficiaries. The exact nature of the services and the path into the Hub will depend on the contract under which the beneficiary is covered.

The CBO provides the specified services, along with services to address newly identified needs, and reports to the Hub on what they have provided. The Hub collects this information and manages billing the health system or payer.

### Information-Sharing

IT systems have been developed for sharing information both between the Hub and the health systems and payers and between the Hub and the CBO organizations, but the systems have yet to link these two sides of the Hub’s operations. Information comes to the Hub from the health care systems or payers, and the Hub distributes it to CBOs. The CBOs share information on their services with the Hub, and the Hub then shares this information with the health system partners. This last phase in the information-sharing process is time consuming because information from the CBOs has to be manually entered into the health system EHRs. (In a limited number of cases, the CBOs can directly enter information into the health system EHR, but they must also share this information with the Hub, not avoiding the need for double entry.) The Hub can specify the system that is used to share information with CBOs, but the health system partners use a variety of systems, requiring the Hub to learn each system to share information.

Billing information is sent from the Hub to the health system partners using a separate system. The Hub receives information from the CBOs on the services they have provided and Hub staff translate this information into billing codes, which are entered manually into the health care partners’ billing systems. They are currently working with a software vendor to develop a new product that will facilitate this process so that the billing data do not have to be manually entered. Developing this system has been challenging because of the difficulty managing billing for care coordination and care management. Simplifying the billing codes for the kinds of services that the Hub manages would greatly reduce the administrative burden of billing.

The VAAACares staff contrasted their system with other referral systems that simply send out referral information to a list of provider organizations. Those systems track whether a referral was made and, at most, whether an organization responded to the referral. A referral is considered successful for the originating organization when a receiving organization responds. However, the system does not collect any information on the services that were actually provided to the referred beneficiary or on the quality of those services. The system that VAAACares uses to share information with its service provider network collects this deeper level of data, enabling monitoring at a deeper level. If a health system or payer contracts with the Hub, they can have a higher level of assurance that services are provided with fidelity than if they used one of the referral platforms.

The Hub has invested in systems to capture data on care transitions. As one informant explained:

We purchased technology specifically for that so we can track [care transitions]. We have the technology where we capture the data, we have some background on the patient or the member and then we capture what our intervention was. And then we can track it and tell you we know the previous hospitalizations and such. We can tell you subsequently what happened after our interventions.

There are also separate information systems for sharing information with the federal government, including reporting required by grants from ACL and separate systems for reporting to state and federal agencies on aging, transportation, and housing: “We have four different housing databases.” Finally, the Hub lacks access to information on utilization of acute care and costs of care, which limits its ability to assess its impact on total costs of care and the success of individual CBO providers in keeping beneficiaries out of EDs and hospitals. These data eventually become available through the Medicaid claims, but the lag makes it unactionable.

### Financing

Sixty-five percent of Bay Aging’s revenues come from VAAACares contracts. Braiding and blending of revenues from multiple sources occurs when additional HRSNs are identified and addressed using alternative resources, such as financing for housing or meals. Housing in particular requires alternative financing because the costs are too high to be paid solely by the health care partners. To date, the Hub has been successful in part because of its nonprofit status. As an informant put it:

We’re a nonprofit, and I think that that is significant, that we can operate on a little bit slimmer margin. So we don’t have to gouge in our pricing, but we have been very successful at Bay Aging in selling to health plans, health systems, other health providers and. . . of course the VA is a big contractor with us also.

### Policy Issues

VAAACares staff identified two policy issues of concern. First, there is a concern that the state auditing requirements might make it difficult to continue operating as a Hub located within a nonprofit provider organization, as VAAACares is located within Bay Aging. If the state requires that the organization open the books of the Hub in the same way as is required of Bay Aging, the Hub will be pressured to split into two organizations. This is because the contracts with health care partners have nondisclosure elements that can’t be made public. Those organizations will not contract with the Hub if the contract terms will be public because of their concern over proprietary information. The steady revenue from the contracts is essential to the model, but the auditing requirement is a potential threat. The process of splitting the organization would be complicated and wasteful.

Second, as noted above, the fee-for-service billing process is unnecessarily complex for the Hub because of the effort required to translate service delivery information from the CBOs into billing codes used by each health system partner. These codes are complex and variable across systems for the kinds of services that Hubs manage, such as care coordination. Simplification of the billing codes for these services would reduce the administrative burden on the Hub. Alternately, financing arrangements that require less fee-for-service billing, such as value-based payment models, would be desirable from the Hub’s perspective because it is already able to collect quality measure data from the service providers.

## Community Care Solutions

Community Care Solutions is a Hub operating in 18 counties in Alabama that have a significant rural and elderly population. Community Care Solutions grew out of a local quasi-governmental AAA, Southern Alabama Regional Council on Aging (SARCOA). Established in 1986, SARCOA has a history of direct service provision and contracting with local provider agencies. The decision to create Community Care Solutions grew out of SARCOA’s decision to participate in CCTP in 2013. The CCTP was to be SARCOA’s first entrance into the health care services arena. SARCOA’s director at the time saw a need for the creation of a separate entity outside the quasi-governmental structure of a AAA to act as “lead entity” for the CCTP contract and other emerging programs that married health and social care services, many of which would likely require the organization to have a provider identification number. Through its work with CCTP, Community Care Solutions also began serving patients outside its traditional region, including those in other counties in Alabama, as well as neighboring areas in Georgia and Florida. When CCTP ended, Community Care Solutions looked to continue its work by establishing additional contracts, which again put them into contact with patients in new counties in Alabama. Through its contract with a regional health plan that wanted coverage for its consumers in 18 counties in Alabama, Community Care Solutions established a formal relationship with another AAA, Central Alabama Aging Consortium (CAAC), to provide and organize services for those living in seven counties well outside SARCOA’s traditional service area. Today, SARCOA health coaches provide services in 11 of the 18 counties where Community Care Solutions functions, and CAAC provides services in the other seven counties.

### Community Governance

Community Care Solutions was formed with its own board of directors. In addition, the Hub draws on the community advisory input from both SARCOA and CAAC. Each of these AAAs has its own advisory council that consists of program participants, service providers, caregivers, and community members. The councils give feedback to the AAAs and the Hub on their operations and provide information about the current and future needs of the elderly community.

### Relationships with Community-Based Provider Organizations

Community Care Solutions’ parent organization, SARCOA, is a AAA and contracts with 55 home and community-service providers. In addition, Community Care Solutions partners with CAAC to provide and organize services for those living in counties outside the 11 counties that SARCOA serves for Community Care Solutions. Both AAAs provide social services directly themselves and have longstanding relationships with other CBOs in their communities that they can connect their clients to for necessary services. These AAAs also work outside their traditional service areas in the work they do for Community Care Solutions. In our conversations with Community Care Solutions, staff stated that they hope to be a statewide Hub at some point but that there can be challenges in expanding into some counties in Alabama because of low population density.

### Health Care Partners

Community Care Solutions has two main care management contracts with health care partners: one with a health care provider serving the counties in which it operates and one with a health insurer. The health care provider contracts with Community Care Solutions to meet the necessary performance metrics and outcomes for its patient population that are expected as part of its participation in an ACO. The contract with the health insurer extends beyond SARCOA’s traditional service region, which led Community Care Solutions to partner with CAAC because CAAC was already working in other counties and had existing connections to home and community-service providers in those areas.

### Government Partners

Community Care Solutions does not have any significant relationships with government agencies beyond SARCOA’s role as a AAA, its participation in CMS programs, and its treatment of Medicare and Medicaid beneficiaries.

### Hub Services and Operations

Health coaches are at the core of Community Care Solutions’ work. Health coaches are directly employed through SARCOA and CAAC, but their salaries are covered by the contracts that Community Care Solutions has established with its health care partners. When new clients are identified, Community Care Solutions sends health coaches to connect with patients and conduct an initial needs assessment. The health coaches will then help identify the social services needs of the patients and connect them to the appropriate programs, either those that exist within SARCOA and CAAC or to other CBOs. New clients are identified proactively through claims data from its contracted health plan and health provider and through referrals from its contracted health provider, case managers, and from its health coaches based in a local hospital.

### Information-Sharing

After reviewing the available software for case management and data sharing, SARCOA decided to work with a vendor to develop its own IT system. The software incorporates all case management activities and acts as a system of record for all activities. The software that SARCOA developed has now been adopted by all the other Alabama AAAs (as well as Community Care Solutions), and SARCOA administers the platform for the network of AAAs.

Health coaches are one of the key sources of data for Community Care Solutions’ information system. The coaches conduct needs assessments with clients and input that data along with their narrative notes and information about the services they provide or connect clients with into the system. Using tablets in the field and a cloud-based system, this information is available immediately to all approved users.

To maintain data safety, Community Care Solutions’ IT system uses NCQA standards and minimum access standards to determine which users can see what information. Community Care Solutions also has a segmented data system to keep information that is relevant only to SARCOA or Community Care Solutions separate and not unnecessarily mingle the data.

In interacting with health care partners, Community Care Solutions’ information system does not include a two-way interface that allows its data system to connect with a health care provider’s or health plan’s system. This means that Community Care Solutions must duplicate some of its data entry, first inputting it into its own system and then inputting it directly into the health plan or health care provider’s health system. Community Care Solutions also receives claims information from its health care partners, although these are delivered as a separate monthly file transfer. Community Care Solutions highlighted that becoming an integrated part of its health care partners’ IT systems was likely not high on its partners’ to-do lists because Community Care Solutions is only a small part of their larger portfolio of work, although that is a goal of Community Care Solutions for the future.

In addition to its discussion of duplicate data entry and not being fully integrated into its health care partners’ systems, Community Care Solutions highlighted some additional challenges it faces with its information system. Because data comes from multiple sources, variation in data quality was one issue. To address this, Community Care Solutions has implemented processes to clean and translate data as it comes in. It also discussed a need for more data analysts because it is currently not able to maximize the data it has. More staff focused on analyzing and understanding the data could help to improve its workflows and allow it to present more results around quality improvement and return on investment than it currently is able to.

### Financing

At its start, Community Care Solutions was created using funds that SARCOA had built up through its work as a AAA. These startup funds were necessary for getting Community Care Solutions off the ground because there was little to no external funding available to create a Hub in the early 2010s. In addition, funding stability would have been challenging in the early years of developing the Hub without the funds from SARCOA that Community Care Solutions was able to use. CCTP was Community Care Solutions’ first major activity and was followed by CCTP II, as well as evidence-based diabetes management and nutritional management programs. Today, Community Care Solutions blends and braids funding from a variety of sources, including grants, contracts, and donations. Its key contracts are with two health care partners that include a state health plan and an independent medical practice that is part of an ACO.

### Policy Issues

Community Care Solutions also discussed several policy issues that it has faced. When it comes to funding, it discussed the importance of finding funding to pay for hiring, training, and building up a well-prepared staff with appropriate expertise and ability to understand the Hub’s practices, policies, and information systems. This funding is needed both before a Hub can really get off the ground and to sustain it moving forward. Although it reported seeing increases in these funding opportunities for newer Hubs since Community Care Solutions began, it highlighted the importance of sustainable funding and getting the timeline right for receiving the initial funding and getting staff hired and trained before a new program or project begins.

Another policy area that Community Care Solutions discussed was the growing emphasis from CMS on screening for SDOH. In addition to expressing support for this policy shift, Community Care Solutions also highlighted a desire for CBOs to get credit for the work involved with screening for SDOH, for referring patients to resources to address their SDOH or HRSNs, and for following up with patients to make sure that the referral is successful.

Finally, Community Care Solutions expressed a desire for more consistent standards for programs so that the services provided and the expectations for what a Hub does is similar across both the state and the country. Community Care Solutions also felt that policies supporting this work should be aligned with the standards. However, it did highlight that, although structure through standards could be beneficial for improving consistency, allowing for flexibility is important so that CBOs and Hubs can figure out how best to organize, staff, and run their Hub and networks.

## Direction Home Akron Canton Area Agency on Aging and Disabilities

Direction Home Akron Canton Area Agency on Aging and Disabilities (DHAD) is a AAA operating in four counties in Ohio. It is part of Direction Home LLC, a network that includes all 12 of the state’s AAAs. A key program that the Direction Home LLC network provides is to support acute care transitions. DHAD acts as the Hub for this program. The acute care transitions program originally began in response to CCTP in 2012. After that program ended in 2017, DHAD began exploring alternative contracts to continue providing acute care transition support and began formally contracting with a state health plan in 2018. Initially, the contract was specifically for the health plan’s Medicare Advantage population in a few counties in the state but eventually grew to include all the plan’s enrollees throughout the state’s 88 counties.

### Community Governance

DHAD does not have a community governance structure that is specific to its Hub work. However, as a AAA, DHAD does have a board of directors that consists of 22 members representing health care and business professionals and community members. All members of the board have experience in health, long-term care, and community services. In addition, DHAD receives input from community members through an areawide advisory board. The board consists of approximately 35 representatives from the four counties that DHAD serves as a AAA, and half of the members are over the age of 59. The group meets on a quarterly basis and discusses such topics as provider allocations and area plan recommendations, advocacy training, agency updates, and other topics that relate to older adults in the area. The president of the areawide advisory board also serves as a member of DHAD’s board of directors.

DHAD staff highlighted the value of having a AAA act as Hub by emphasizing that they have long held “the role of assessing need, providing information, referrals, and support to people across programs,” which “helps ensure barriers and gaps are met outside of the patient’s transition needs.”

### Relationships with Community-Based Provider Organizations

The network of CBOs that participate in DHAD’s acute care transition program include all 12 AAAs in Ohio, allowing the network to provide coverage to members of their contracted health plan in all counties in the state. The health plan contracts directly with DHAD, and the other AAAs act as subcontractors. In discussions with DHAD, it highlighted that it “[has] a very strong state association within Ohio across the AAAs” and that “the value in just sticking with the AAAs is we know each other. We have worked with each other for years. We openly share best practices with one another. We’re better together as an organization.” Although DHAD does refer individuals to other CBOs in cases in which individuals need services that the AAAs do not directly provide themselves, DHAD does not formally subcontract with these CBOs for this program. DHAD does see potential future partnership opportunities with other CBOs in behavioral health and addiction medicine because it does not currently have as much expertise or experience addressing these needs.

### Health Care Partners

DHAD has health care partnerships as a Hub with a state health plan and with nearly all hospitals and health systems throughout the state. In many hospitals, RNs participate regularly in Ground Rounds to identify potential patients who could benefit from the acute care transition support that is provided by the network. The health coaches also interact with the patients’ primary care practices. As was explained during our discussions with DHAD staff, “the registered nurse [who acts as health coaches to participating patients] can call physicians directly if needed, but at a minimum, the primary care physician receives an outcome-based summary on our interaction with their patient,” as well as the detailed medication reconciliation that was completed by the health coach in the patient’s home.

### Government Partners

For the overall work that DHAD does as a AAA, it partners closely with the Ohio Department on Aging, the Ohio Department of Medicaid, CMS, and ACL. These partnerships benefit the patients who participate in the Hub’s acute care transition intervention because the health coaches are able to refer eligible patients to other programs supported by government funding and partnerships.

### Hub Services and Operations

Under the current iteration of the network’s acute care transition intervention, a health coach (who is an RN) works with patients that could benefit from additional support as the patients transition from a hospital or SNF stay back to their homes. Patients are identified either by the health plan or through attendance at hospital Ground Rounds. The health plan’s referrals for the intervention come in the form of a daily list of patients with an inpatient stay or an upcoming scheduled procedure or surgery. Additional participants are also identified by staff who are a part of the network attending virtual Ground Rounds with hospitals throughout the state to hear about potential patients who could benefit from acute care transition support. These patients still must be enrolled in the health plan to be eligible for the intervention, but they are sometimes not on the list that DHAD receives from the health plan because they do not fall into the categories that the health plan looks for to identify potential participants.

Once a referral to the intervention has been made, staff try to connect with the patient before they leave the hospital, SNF, or rehabilitation facility, either through an in-person or telephonic visit. For patients in SNFs or rehabilitation facilities, the health coach will stay in contact with the facility to receive updates on the patient and identify the likely discharge date. Once a patient is discharged, the health coach conducts a home visit within one to three days of discharge. During this home visit, which lasts between 60 and 90 minutes, the health coach will review discharge instructions with the patient, confirm follow-up appointments, discuss potential red flags or symptoms of decline they want to watch out for, conduct a medication reconciliation, evaluate for any social service needs, make referrals, and conduct a fall risk assessment. As part of the intervention, DHAD is also starting to pilot a caregiver support program in which the health coach identifies if there are any needs of the patient’s caregiver that are not being met. The home visit is then typically followed by two phone calls between the health coach and the patient over the next 30 days, in which the health coach will tie up loose ends on any referrals that were made, identify any new areas of concern since the previous interaction, and reinforce any education or information that was given during the visit. The intervention ends at 30 days post-discharge.

### Information-Sharing

Across DHAD, several systems are used to collect, track, and analyze patient data and the services that the AAA provides. The data from these systems are used to produce regular reports for a wide variety of partners and needs. In addition, the Hub collects weekly satisfaction surveys from clients using the AAA and Hub’s services.

For its Hub program, DHAD has a specific data system that gathers information from health coaches across the state on the services they provide in the acute care transitions intervention. This system is not interoperable or integrated with the health systems or the health plan with whom DHAD partners. Data from the health plan about potentially eligible patients for the intervention are based on the health plan’s claims data and is delivered to DHAD on a regular basis. The Hub also uses a statewide health information exchange, which allows DHAD to quickly obtain information about patients and program participants. Overall, across both the Hub and DHAD’s larger portfolio of programs, staff expressed a desire for a more integrated, interoperable system.

### Financing

The Hub’s work was initially financed through CCTP and did not require significant additional startup funds. By braiding and blending DHAD’s overall funding sources for its programs, it was then able to cover the gap between the end of CCTP and the start of its contract with the state health plan so that it could keep key staff onboard and not lose the institutional expertise it held from implementing and running the network’s CCTP work. The current contract for the Hub’s work is based on a per-intervention payment. Recently, this payment was renegotiated to incorporate support for some of the work done outside the direct services provided through the intervention, including finding and updating patient contact information, collecting additional information for the health plan about patients’ health and social needs, conducting the fall risk assessment (which was more recently added to the intervention), and an administrative fee for DHAD. In addition, there is a risk component to DHAD’s payment should the network not meet quality goals regarding 30-day readmission rates and patient satisfaction.

DHAD’s larger portfolio of work is funded through Medicaid, the Older Americans Act, and other government funding, nongovernment contracts, state and local funding, and other sources. DHAD also discussed a useful cost model framework that it created that helps it quickly cost out potential programs.

### Policy Issues

DHAD staff highlighted two main policy issues in which they thought additional guidance or future policies could help to better support Hub work. First, staff discussed the need for improved interoperability and integration of IT systems used across service providers and partners. They pointed to the support given within health care for providers to improve their health information systems to reach meaningful use standards and suggested that there is a need for “that investment in long-term care, long-term services and supports providers” as well so that they are “able to really scale up” their systems.

Another policy area that DHAD staff highlighted was around accreditation requirements. Specifically, staff questioned whether all partners involved in a contract need accreditation or whether it is appropriate and sufficient for the Hub to have that accreditation without requiring it of those who are acting farther downstream in the process. As staff explained, one of the benefits that Hubs provide is their ability to keep overhead low and ease the contracting and partnership process across health and social care providers while ensuring security expectations and standards are met. However, when all partners are required to reach a certain level of accreditation, that increases costs and burden. As DHAD staff said during our conversations, “the role of the Community Care Hub [is] to streamline infrastructure and keep costs low, but provid[e] that standard oversight that we’ve already built.” This role and value can be diminished if accreditation requirements become overly applied and burdensome.

## Houston Health Department

Unlike the other case studies in this report, the Houston Health Department Hub is still being developed and has not yet begun to operate as a Hub. Planning for the Hub is currently being conducted by three partners: (1) the Houston Health Department itself, (2) a group of population health researchers at the University of Texas, and (3) the Houston Health Foundation, an independent nonprofit organization that creates public-private partnerships to advance public health in the Houston region. The three organizations have been meeting regularly to develop detailed plans for implementing a Hub model. In this summary, we focus on factors that have influenced decisionmaking by the group developing the Hub during the planning process.

Within the Houston Health Department, the group working on the Hub is the local AAA. The Houston AAA is the largest of the 28 AAAs in Texas, and it has already been acting like a backbone organization in some respects. Although the AAA does not contract with payers, it contracts out 98 percent of its services to community-based providers. The only services that are not contracted out are care coordination and caregiver support coordination. The university-based group has experience as principal investigators on an AHC grant from CMS, which supported integrating efforts to screen for and address SDOH across multiple health care systems and hospitals in the Houston region. With that experience, the university-based team brings expertise in identifying HRSNs in health care settings and the challenges of addressing those needs in the community. The third partner, Houston Health Foundation, works closely with Houston Health Department to administer public health programs in the community, such as a community food security initiative, a youth violence prevention program, and a diabetes awareness and wellness network.

### Community Governance

Each of the three organizations developing the Hub has a different governance structure. As part of the city government, the Houston Health Department is accountable to the city administration and the voters. Being located in a governmental agency also means that the Houston Health Department is accountable to the complex bureaucracy of city government. The university-based team did not have a community governance board for the AHC that they created. Houston Health Foundation has a governing board that is responsible for the entire organization but is not designed to represent the Hub network or the community served by the Hub. In planning discussions, the three organizations have discussed creating a community governance board using a community engagement approach, but that process has not yet been initiated.

One of the major issues to be decided in the planning process, which concerns the varying governance structures of the organizations, is where the Hub would be housed. Initially, the Houston Health Department was considered the appropriate home for the Hub because it houses the AAA and has the most extensive connections with CBOs. However, the bureaucratic processes that are required to operate within a city government, such as the contracting issues discussed below, were found to be overly burdensome. Consequently, the current plan is for the Hub to be housed within the Houston Health Foundation.

### Relationships with Community-Based Provider Organizations

The network of CBOs that have a history of providing services under contract with the Houston Health Department would serve as the core of the CBO network for the Hub. There are about 40 such agencies, and they tend to be large for CBOs. For most of these organizations, the Houston Health Department is not their only contractor. The AHC also has a history of working with CBOs that provide services to address HRSNs, though not through contractual relationships. As part of the planning process, the AHC inventoried the existing programs and identified 150 CBOs that could be part of the network. The organizations in the AHC network provide a broad variety of services, including home food delivery, access to community meals, diabetes prevention, education, housing, housing navigation, travel vouchers, home improvement vouchers, and services for adults to combat loneliness. Some of the organizations are quite small.

### Health Care Partners

It is not yet clear who the main health care partners would be, and all the possibilities remain under consideration: local hospitals and health systems, Medicare Advantage plans, and Medicaid Managed Care plans. The Houston Health Department has a history of partnering with local health care systems on care transition projects, so there is a basis on which to build those relationships for the Hub. The department also has a history of working with United Healthcare to provide care to hard-to-reach populations. The health systems that partnered in the AHC model would also be natural partners for the Hub.

### Government Partners

The Houston Health Department regularly works with other arms of the city government, such as work it does with the housing authority to provide housing vouchers to people at risk for homelessness. However, within Harris County, where Houston is located, there are many municipalities. Part of the planning for the Hub has been strategic thinking about how to include more of these municipalities. The planning group has also had discussions with the state Medicaid office about how they might work with Medicaid payers.

### Hub Services and Operations

Multiple models for Hub operations are being considered. The strategy is to start on a small scale by contracting for a clearly defined set of services with which they are familiar, such as post-hospital transition care. The scope of services could be expanded if those initial contracts were successful. However, the Hub would function differently from how the Houston Health Department has worked with hospitals in the past. The department used to embed a staff person within the hospital and then start the transition process from the hospital prior to discharge. The embedded staff were able to review the census every day to identify patients; they may have been looking for patients with specific conditions, such as CHF. In the Hub model, the department expects that the referral would come from outside the Hub (e.g., from an MCO) and that the Hub would then need to identify the appropriate CBOs to provide needed services. The Hub might identify more needs than were initially identified, and it might make referrals beyond those initially requested by the referral source.

There is also discussion about how best to use what was learned from the AHC model for developing the Hub. The AHC model was based around screening patients for SDOH. Using the results of the screening, AHC would then provide navigation related to SDOH needs for one year. However, the Hub model does not have clear guidelines about how these operations should be structured. Having to work with each payer and meet their needs for social services is more challenging. In addition, the Hub involves direct contracting with the CBOs and monitoring of the services, which was not part of the AHC model. Ideally, according to one discussant, a person would be referred following screening to the Hub and the Hub would have the decisionmaking ability to route the person to the right CBO to get the services they need, and this would be an integrated system.

### Information-Sharing

The Houston Health Department is currently considering using a commercially available platform for its Hub EHR because it has used it in the past, and several of its CBO and health system partners already use it. However, it is not completely clear that the platform will be able to do everything that is needed for the Hub, including sending referrals across systems. The department is currently investigating how other Hubs have set up their EHR systems. They told us: “So that’s where we are also looking at some other Community Care Hubs and different states to determine how they work that [data-sharing] process out so that we can. . . purchase a new type of system that works, that’s compatible with [the system], and that is accessible by the community-based organizations.” The information systems for the AHC model did not require sharing information with CBOs electronically because the system only made referrals. No health-related information was shared, and closed loop referrals were not tracked.

Several other challenges related to information systems were mentioned. There is a need for information security, which the selected system provides, but it needs to be strengthened when

CBOs get involved. There has to be consideration of where the information will reside. In the AHC model, the university was able to store information because they are a CMS entity. The cost for IT is considerable, and it involves upfront investments that need to be paid for. To use the selected system, the Hub would need an IT team, a quality improvement team, and the hardware infrastructure. The CBOs need training in the technology and reliable internet service in their area, which might be beyond anyone’s control. Working with the CBOs around technical skills is challenging because so many of their staff are volunteers, and they have high turnover.

### Financing

The Hub planners anticipate that the financing for the Hub will come primarily from contracts with Medicaid managed care companies. There might be some other sources, such as the state fund for care for the uninsured and local care systems. The Hub planners hope to get some grant support to help launch but would rely on contracts for sustainability. They have been learning about strategies involving blending and braiding sources of financing, but they are wary of being put in a position in which they have to provide financing for services outside their contracts. In the past, the department has had the experience in which they provided services for a health system and demonstrated good outcomes, but the health system nonetheless stopped providing the service as soon as the external funding ended. In some cases, there are services that can be billed to Medicaid, but they are currently provided by the Houston Health Department for free. In these cases, the payers will not be interested in contracting to pay for what they are currently receiving for no cost. As one discussant said, “So there’s all these models that we’re trying to, you know, work through, but at the same time not undervalue what we what we offer and what we can bring to the table.”

### Policy Issues

Discussants expressed concern that the incentives for payers to work with Hubs are not strong enough. As one discussant said, “We are putting money into the sick care system where we don’t want this work to reside, and then rely on that system to be benevolent and contract with Hubs.” It might be important, therefore, for CMS to have requirements regarding how money flows to Hubs and CBOs. Another concern is with duplication of care coordination efforts, with care coordination happening within health systems (often in multiple locations) and within the Hub. It would be more efficient to figure out one location from which to coordinate care. Finally, establishing the Hub would be facilitated by expanding Medicaid.

## Partners at Home

Partners at Home is a Hub located in California, providing services in all 58 counties in the state. Partners at Home is the name of the Hub network that is a division of the larger Partners in Care Foundation (Partners) organization. The Hub grew out of work done in the Los Angeles

County area as a part of the Nursing Home Diversion Program under California’s Medicaid Waiver. That led to a statewide contract with Blue Shield. Partners in Care also participated in CCTP. Partners recently hired a new senior director and director for the Hub to support ongoing Hub activities now that the core infrastructure has been built out. The Hub uses a centralized approach to organizing its different partners and types of programs. All financing, billing, and compliance is centralized in the Hub and disseminated to partners. Leadership in the Hub is active nationally in the Partnership to Align Social Care, in which they participate in creating a core set of functions for Hubs.

### Community Governance

Partners at Home uses a member agency model for governance. The board does not have a bylaw structure. Most members are CEOs or their designates at partner organizations. Information from the Hub is shared at the member agency level. All members are invited to regular monthly meetings for briefings and for input and to identify issues. Partners is a direct service provider as well. The Hub works to provide feedback on information from member agencies to the payers and other partners. The Hub is working to formalize the process of collecting information from the member agencies, which is then fed back to the payers to inform future programs and contracts. One mechanism that has been used to elicit information on programs is the Net Promoter Score through patient satisfaction surveys, which is required for all beneficiaries served under its Blue Shield contract.

### Relationships with Community-Based Provider Organizations

The majority of CBO partners specialize in home care and in care management and care coordination and include local organizations, such as adult day health care centers, senior centers, home care agencies, aging and disability serving organizations, Meals on Wheels, and family services organizations. Service providers vary based on the counties and the contracts that Partners at Home has in a given area. The Hub looks at it primarily from a county-level perspective, identifying community organizations in that county and their ability and capacity to meet the projected volume expectations from the payer’s side. The Hub uses a “friends-of-friends” model—or organizations that look like Partners—to identify new partners, particularly those that operate statewide. The value of organizing into the Hub is both that health care organizations do not need to have hundreds of contracts with service providers and to provide the Health Insurance Portability and Accountability Act (HIPAA) and compliance training to partners so they are trained to provide services for health care organizations. The Hub model allows member agencies to focus on what they do best (beneficiary social care and well-being) while the Hub focuses on the administrative services of health care contracts.

### Health Care Partners

Through the larger Partners organization, Partners at Home holds contracts with health systems, hospitals, medical groups, and health plans, including Medicare and Medicaid but often with all business lines, which are negotiated individually and vary in scope. The contracts are based on the health care partner’s needs, the target population, and the types of providers available in the area(s) of operation.

### Government Partners

Partners at Home did not note any government partners for service delivery through its Hub. However, Partners at Home has engaged the state Medicaid agency in the CalAIM rollout and has received funding through government agencies, such as ACL, for infrastructure development.

### Hub Services and Operations

The Hub function is to first identify the needs and to then identify the solutions, codesign them, and implement them. Care coordination is the primary service provided by the Hub and its partners. It can be provided through short-term engagements (30 to 90 days) or longer-term engagements. Within the care management model, there are a variety of services provided. One service is supporting transitional care from the hospital for Medicare and Medicaid beneficiaries. Another set of services revolves around personal care, homemaking, nonmedical respite services, and meals, including medically tailored meals. In 13 counties, the Hub has a self-management program under the Older Americans Act. These are evidence-based programs to help people adopt better behaviors to achieve better health outcomes.

The Hub plans to add more services over time that align with the organization’s mission. The Hub added private duty care, nonmedical home care, and personal care respite services because these services aligned well with the mission of supporting people in the community.

Services begin with a telephone visit or encounter that triggers the case rate. Each service starts with an assessment of the beneficiary and receipt of services for 30 days. The payers identify beneficiaries and initiate the referral. The Hub reviews the referral to ensure all the necessary information was delivered to the Hub. Then, based on the coverage area, the capacity of network members, and the members’ ability to take on additional cases, the beneficiary gets assigned to a network member. Service delivery is driven by the scope of work with the health care partner, although a screening is done with each beneficiary. The Hub leverages its resources to provide additional support, such as buying mattresses or other equipment to support beneficiary needs. The Hub has an urgent needs fund that is used to address pressing issues that are not covered by the payer.

### Information-Sharing

Partners at Home uses Salesforce as its EHR for many of its health care contracts. Referrals come into the Hub, which moves referrals to partners based on capacity, scope of the member agency, demographics of the beneficiary and the organization, and geography of the beneficiary and the organization. The Hub also manages a call center that receive referrals. Because the main service provided is care management activity, the Hub tracks whether referrals are completed (closed loop) and whether services are provided in a timely manner. Quality is measured through the net promoter score and several process measures, including timeliness of outreach and timeliness of service delivery. In addition, each contract has its own metrics that are tracked as a part of service delivery.

The Hub creates reports and shares data regularly with payers and service providers. For service providers, the Hub creates benchmarks as a mechanism to motivate its network. For payers, reports are contractually agreed on in the scope of work. These reports are shared over a SFTP or secure email because it includes PHI.

Partners at Home reported that it struggles to get outcome data, such as claims and health outcomes, from payers and providers. Defining the outcome in contracts has also been a struggle because social care is a piece of the larger health and utilization of a patient. Another area that is a struggle is the lack of consistent terminology used between medical care and social care. The Hub noted a conversation with a local IT vendor who recommended that there should be work done between the plans, social care, and medical care to collaborate on common information standards for the SDOH marketplace. Right now, there is complexity and inefficiency in the system. The California Department of Health Care Services is flexible and innovative with its programs, leading to many programs with differing requirements. Even within a county, there are several programs operated by plans that vary in their requirements.

Equally challenging is the diverse set of approaches that each health plan or provider can set out as a scope of work to achieve the same result of keeping people independent and well in the community. This multitude of care “roadmaps”—each ending in the same destination but built on its own unique requirement of assessments, IT documentation, and other varied requirements—leads to greater cost and inefficiencies for CBOs and Hubs. An agreed to, uniform roadmap to a care plan would lead to greater efficiency, lower cost, and better outcomes for those under care.

### Financing

Partners at Home received startup funding from The John A. Hartford Foundation in 2012–2013. From there, the Hub developed contracts to sustain itself on service delivery activities. At this point, the Hub can sustain itself with the case rate for services provided as the Hub. Although grants are helpful to start, they can be “mercurial.” To become sustainable, organizations need to shift to contracts. Grants can continue to be useful in energizing or expanding the operations of the Hub. Some contracts are per-member per-month payments that function similarly to case rate payments. One service that is typically not covered in the case rate is outreach, which is uncompensated.

According to Partners, CBOs do not struggle with the braided and blended financing model because that is how they have traditionally operated. Payments to the partner organizations in the network are passed through the Hub to the partner organization. The Hub negotiates an administrative fee in each of its contracts with payers and has separate contracts with partners to pay them for the services provided.

### Policy Issues

Partners at Home identified a few issues that might require policy interventions. First, the Hub noted that there needs to be policies recognizing how social care operates. Specifically, it noted that health care operates using claims and encounter data, whereas social care does not use that model to track its work. There need to be policies recognizing how social care operates and how that framework can be used in conjunction with the health care framework for care. Second, the Hub noted that licensure issues might be problematic for social care. They noted that social care uses an alternative workforce that should have different standards because they are not facility-based and do a lot of their work during home visits and tracking down beneficiaries where they are. Third, the Hub noted that there needs to be consistency in the services and contracts available to social care organizations. In many cases, social care providers receive lists of patients and are tasked with outreach without payment, or they receive an overwhelming number of referrals at once and then receive none for extended periods of time. Finally, to promote Hub activity, the Hub advocated for increased support from organizations—such as America’s Health Insurance Plans (AHIP), American Hospital Association, American College of Emergency Physicians, and government agencies, such as CMS, the Office of the National Coordinator for Health Information Technology, and the CDC—to promote the integration of social care.

## Western New York Integrated Care Collaborative, Inc

Western New York Integrative Care Collaborative, Inc. (WNYICC) is a Hub operating in the 15 westernmost counties in New York, with most of its services focused on the eight counties including and surrounding Buffalo. WNYICC grew out of the efforts of two county-based AAAs and their nonprofit partner agencies in the area who wanted to capitalize on the increased attention that health care institutions were paying to addressing SDOH. The AAAs leveraged their networks to create WNYICC as a separate standalone 501(c)(3) entity to act as a contracting backbone organization in 2014. Because of its start with AAAs, the first few contracts that the WNYICC had were with Medicare Advantage organizations, focusing on the over age 65 population. The Hub currently consists of 54 partner organizations, including two departments of health, one Center for Independent Living (CIL), eight AAAs, and 43 social care agencies. The Hub is expanding its network of providers to include supports for children and families, as it is preparing to apply to be the lead entity Social Care Network for Western New York under New York state’s Medicaid section 1115 demonstration renewal.

### Community Governance

The WNYICC board consists of 11 members. All members of the board are either leaders of the member CBOs or former leaders of the CBOs. Board members are elected to three-year terms that may be renewed annually. The four officers of the board make up the executive committee, which has the authority to make decisions on behalf of the full board. The 54 network member agencies are all voting members. Each network member agency is represented by a network agent who has the authority to vote on behalf of the agency. The voting network member agents meet annually to review an annual report and vote to approve the slate of the board. Additionally, network members are encouraged to join one or more of the six committees on the board, all of which are chaired by a WNYICC board member and coordinated by the WNYICC team: (1) Finance/Audit; (2) Network Program; (3) Compliance; (4) Quality Assurance/Data; (5) Diversity, Equity, and Inclusion; and (6) Emerging Business. Some network members are more engaged than others, which is their option. WNYICC’s work is informed by the feedback received in the committees.

Many CBOs are very busy or have small staffs, with some consisting of one employee and many volunteers. Thus, the Hub has, in practice, been flexible with respect to its expectations, and CBOs are not excluded if they are not able to participate on the committees. In addition, the Hub works to actively engage network members by providing monthly lunch and learn opportunities; providing updates on national, state, and local policy issues, such as New York state’s upcoming Medicaid section 1115 demonstration; publishing quarterly newsletters; sharing information through social media; and holding an in-person meeting every June.

### Relationships with Community-Based Provider Organizations

WNYICC has a network of partner CBOs that has expanded from the base of the CBO networks of the two AAAs that originated the Hub. The current network includes a wide variety of CBOs that provide food delivery services (e.g., Meals on Wheels) for people with intellectual and developmental disabilities, temporary and emergency housing, care coordination, and services for criminal justice system–involved individuals. As new needs emerge from either a contract or from external events, the Hub works to add more agencies to its network. For example, in 2023, the Hub focused on bringing in agencies in inner city Buffalo because there was a significant racially motivated shooting that rocked the region. Typically, the Hub uses “friends of friends” (i.e., CBOs that are recommended by existing CBO partners) to build the network. According to the Hub, it is an easy choice for the CBOs to decide whether to join the network because there’s no cost to the CBO. CBOs get all the benefits of being in the network— including advocacy on their behalf and the potential contracting opportunities—and the CBO can be as engaged or not engaged as it wants. All contracted partners are provided training through WNYICC’s Training Academy on compliance, program workflows, documentation, how to receive and handle referrals, and invoicing WNYICC for the services they deliver.

WNYICC also has partnerships with eight AAAs all at the county level in its region. In addition, there is one CIL with affiliate offices in all 15 counties that WNYICC serves.

### Health Care Partners

The majority of the WNYICC’s current contracts are with Medicare Advantage plans. The Hub also has several contracts with Medicaid plans for the Diabetes Prevention Program (because it is a billable Medicaid service in New York state) and several value-based contracts with Medicaid long-term care plans. The Hub also has a few contracts with commercial plans. With the Hub’s biggest health plan contracts, they meet weekly to talk through all the different programs included in the contract and take a partnered approach to care delivery. The focus of the weekly meetings is on co-developing processes and procedures, setting up referral pathways, and developing minimum referral guidelines. With other health plans, the Hub might sign a contract and not receive many referrals. The most successful partnerships, from WNYICC’s perspective, have been those with regional health plans, particularly those that try to engage and partner with local agencies.

In contrast to health plan contracting, the Hub has struggled with contracting with health systems and providers. As a part of the ACO REACH Model, the Hub was close to having a contract with a system to implement its Health Equity plan, but the system decided to contract elsewhere. According to the Hub, provider budgets are slim, so they may prefer to build supports rather than buy them from (or contract with) outside organizations. In contrast, health plans can bill for services, so they are less reluctant to engage.

### Government Partners

WNYICC has partnerships with two departments of health in its region. Although there is mostly benefit for partner agencies, the Hub continuously works through challenges for some partners to sign contracts, particularly health departments and other government agencies or small agencies who do not have adequate insurance. The contracting process with governmental entities can be protracted and take multiple rounds of legal review. WNYICC works with its network members to help reduce the barriers to contracting. It has also received funding through ACL for infrastructure development.

### Hub Services and Operations

WNYICC coordinates a variety of services for health plans and is constantly asset mapping, with the goal of expanding the services available to health plans. WNYICC’s goal is to not provide services themselves but rather contract with CBO service providers based on contract stipulations with payers. However, WNYICC’s community nutrition program manager, who is a registered dietitian (RD), does deliver the medical nutrition therapy program because of a lack of RDs in the network. The Hub is starting to contract with independent contractor RDs to fill this gap.

The most common service provided is the post-discharge meal delivery program. The service includes two weeks of meals after at least one overnight stay. In any month, there are 80 to 100 members using the service. The Hub also offers multiple coaching programs. Members are assigned a coach and screened for SDOH needs, and then the coach works with them for up to 12 months to address the concerns that came up during screening. Coaches have the option to enroll the beneficiary into one or more evidence-based programs. The coach helps the member get necessary resources needed to address the needs in their care plan, helps fill out applications, and assists the member in setting goals. The Hub also offers a fall prevention program. A service provider does a walkthrough of the beneficiary’s home (looking for loose rugs, grab bars, light switches, etc.), helps the beneficiary get a personal emergency response system, creates a mobility plan, and enrolls the member in an evidence-based fall prevention workshop, such as Tai Chi, delivered by a network member. Similar to the fall prevention program, the Hub offers a caregiver support program that includes the beneficiary and their caregiver. The plan pays for the caregiver to receive support and coordination of services from the health coach (even though the caregiver is not the beneficiary), knowing that it is going to benefit the beneficiary. The Hub also has a program called Healthy IDEAS, which is an evidence-based program modeled as a community emotional wellness program. The program provides education on what depression is and where to find resources and treatment and then focuses on behavioral activation to start setting small goals to help the member begin feeling better and reduce stress. Finally, the Hub offers two diabetes programs: the Diabetes Prevention program, which is a CDC-recognized, yearlong group class, and the Diabetes Self-Management program. For the Diabetes Self-Management program, there are some issues with credentialing because the program requires dietitians that are not normally employed by CBOs.

### Information-Sharing

WNYICC uses a centralized electronic client record that was built to track and manage referrals, document program delivery, and submit claims. The goal of the system is to reduce the burden on the CBOs, who may use one platform, and payers and providers, who may have another system that they want their contractors to use. Every referral is entered into the system’s referral management section by the WNYICC administrative team, who verifies the referral by checking that the members have the proper eligibility requirements. Once the referral is verified for eligibility, it is assigned from the referral management queue to the program delivery partner. Each program has a documentation center. Referrals are assigned based on the contract, the service providers in the area of the referral, and the capacity of the CBO to accept the referral.

The Hub can receive referrals in one of four ways: (1) through a HIPAA secure link on its website; (2) through a fax; (3) through the regional health information exchange’s direct messaging from a provider, plan, or health plan’s case managers; or (4) through self-referral for enrollees in another WNYICC program. WNYICC delivery partner coaches and RDs are encouraged to cross-refer to additional programs that might benefit their clients. WNYICC’s outreach coordinator engages with providers in the region to educate them on WNYICC programs and the referral process.

As a part of the programs offered by the Hub, WNYICC’s contracted delivery partner staff perform an SDOH screening with enrollees. Their responses are tracked to show changes in need and whether enrollees achieved their goals through the coaching programs. A key metric that the Hub uses to measure the programs’ efficacy is whether SDOH concerns are addressed. Other metrics are program-specific and include such metrics as PHQ-9 score changes from the Healthy IDEAS program; changes in weight, vegetable intake, and malnutrition scores for the Medical Nutrition Therapy program; and satisfaction with services for the meals programs.

WNYICC would ultimately like to build an integrated data system to reduce the amount of data entry and allow providers to see social care information in their clinical record. The Hub is in process of starting a project with a data integrator to reduce the manual data entry and report generation process time. Currently, the Hub does not have the bandwidth to complete individual reports for all programs because of the time required to generate reports manually. However, providers and plans may request individual client reports, as needed.

Program reports are tailored to the contract and program. Reported metrics are negotiated with the health plans. If the program is referred by a doctor, there is a report sent to the referring provider as well. In addition to sharing reports externally with health plans, reports are also generated and shared as a part of the quality assurance program within the Hub. Data is reviewed in committees on the board. The Hub tracks several metrics overall on its programs, including the number of enrollees per program, how many enrollees stay in the program, how many complete the program, and whether there were improvements in metrics for those who complete the program. These data are used as benchmarks to track performance over time.

### Financing

In 2017, the Health Foundation of Western and Central New York provided grant funding to WNYICC to develop its infrastructure and network. One of the participating AAAs, Erie County Department of Senior Services, had developed a diabetes self-management program that was used to show the ability for WNYICC to create programs, become accredited, and use them to gain contract funding. The funding from the Health Foundation of Western and Central New York was used to hire a full-time director of business development to operationalize the program by developing a network, acquiring contracts, developing referral pathways, and developing a training academy.

Once the initial funding was in place and the network was established, WNYICC began contracting with Medicare Advantage plans in its region. Approximately half of the budget of WNYICC comes from grants, while the remaining half comes from contracts. Most contracts relate to service delivery, but there are a few related to technical assistance and training. All the money from the contracts comes to WNYICC, and then WNYICC pays its partners through individual subcontracts. CBOs submit an invoice, and the Hub pays them for their services. Contracts with CBOs are negotiated individually for each agency and program. Approximately 65 percent of payments go directly to a CBO partner, and the remaining 35 percent cover the administrative costs for the Hub. Administrative funds go toward staff time to do referrals; toward contracting, marketing, and operational staff; toward paying for a third-party biller; and toward developing and supporting the IT system.

WNYICC tracks funds at the program level. WNYICC noted several challenges to financing that make it difficult to expand its work. The first issue mentioned was low reimbursement rates from Medicare and Medicaid for certain programs, particularly the Diabetes Prevention program. Another issue was the lack of minimum referral guarantees in contracts. Without these guarantees, CBOs have a hard time staffing up to meet a potential contract demand. In addition, there are few dedicated funding sources for CBO capacity-building. WNYICC is hoping that funding for capacity-building with CBOs will be included in the New York state Medicaid section 1115 demonstration amendment when it is approved because post-pandemic, CBOs lost staff (and they already had a high rate of turnover). Funding was available for other institutions, such as nursing homes, but similar funds were not available to CBOs. Finally, WNYICC noted the need for additional support explaining and supporting braiding and blending funding sources among its partners. Similarly, CBOs are less comfortable with contracted work because most of their work has been grant funded, in which funds pay for a project over time, as opposed to a service to be completed.

### Policy Issues

WNYICC identified three policy areas that would be beneficial to its work. The first is dedicated funding to support social care data platforms. Health care organizations received funding to adopt electronic medical records, but social care has not been provided with dedicated funding for these efforts. Second, WNYICC advocated for the development of standard metrics. There are regional, state, and contract-level differences in metrics, as well as metrics that vary by population (i.e., different metrics for Medicaid versus Medicare patients receiving the same services). These differences create administrative burden for the Hub and are challenging to CBOs who often provide services regardless of payer. Finally, the Hub advocated for policies to increase the visibility of backbone organizations and support engagement. WNYICC noted that it sometimes struggles to get engagement with plans or health care providers despite its best efforts to communicate the efficacy and cost-savings of its programs. As new policies and requirements are developed for addressing HRSNs on both the state and federal levels, WNYICC advocates for mandates for health plans and providers to partner with social care experts at local CBOs or Hubs.