# Appendix B Discussion Guide for Hub Case Studies

## Overview of the Hub Organization

1. To begin, can you tell us a bit about [Hub name] and your role(s) there?
  a. Can you please tell us more about how your role specifically relates to the coordination of health and social services (either individually or as part of a broader network)?
2. How and when did [Hub name] come to be?
  a. Did the Hub grow out of a previous organization, such as an AAA?
  b. Has the organization been part of other initiatives, such as AHC or ACO?
  c. How did the network of CBOs develop?
3. Does [Hub name] have a formal community governance structure? Can you describe that structure?
  a. How are the CBO network partners involved in the governance structure?
  b. How are consumers or people with lived experiences involved?
4. What kinds of staff does [Hub name] employ?
  a. Community health workers?
  b. Social workers?
  c. Other social service providers?
  d. Administrative staff?
  e. Grant-writing or fundraising staff?
  f. Quality and compliance staff?
  g. Technology support staff?
  h. Health care providers or clinicians?
  i. Others?
5. What is [Hub name’s] geographic reach?
  a. PROBE: How has the geographic reach changed since the start of [Hub name]?
6. Describe the population(s) served?
  a. What indicators determine the population(s) served?
  b. How are individuals eligible for the services [Hub name] provides identified?

## Partners

7. Who are the [underlined: community-based organizations (CBOs)] that are part of [Hub name]?
  a. About how many CBOs are in the network?
  b. What types of CBOs are in the network?
  c. What are the main kinds of staff that work at these CBOs?
    i. Community health workers?
    ii. Social workers?
    iii. Primary care clinicians?
    iv. Behavioral health clinicians?
    v. Others?
  d. How does [Hub name] build and manage relationships with CBOs?
  e. Are there challenges that [Hub name] faces in managing the network of CBOs?
    i. Limited provider capacity in some communities?
    ii. Technological capabilities of CBOs with respect to billing, reporting, and sharing data?
8. What about on the health care side? Who are your [underlined: health care partners]?
  f. Do you partner with health systems? Which ones?
  g. Health care payers or health plans?
    i. Probe on Medicare, Medicare Advantage, Medicaid, Medicaid MCOs
  h. Do you partner with other providers or provider agencies?
    i. Private primary care practices
    ii. FQHCs?
    iii. Others?
  i. How are those relationships established and maintained? What are the main challenges in working with payers and health systems?
9. Does [Hub name] have government partners? If so, who are they?
  j. Probe for:
    i. Do you partner with public health agencies?
    ii. Social or human services agencies?
    iii. State Medicaid office?
    iv. Housing agencies (e.g., HUD)?
    v. Any other government partners?
  k. What level of government—federal, state, county, other?
  l. How do you work with your government partners?
10. Are there any other partners in [Hub name]?

## Services

11. The next questions are about the services that the network provides. What are the main services that [Hub name] provides?
  a. Probe for:
    i. Transportation, housing, food security, home-based health care, behavioral health care, care coordination, care transitions, evidence-based programs.
    ii. Does the Hub agency provide any of these services itself, or are all the services provided by partner agencies?
  b. How does [Hub name] determine which types of services to include in the network?
  c. Are there challenges in providing certain types of services that you would otherwise like to provide? Has [Hub name] expanded range of services in its network?
  d. Do you anticipate [Hub name] facilitating access to additional services and for other population groups over time?
  e. Do you screen for social determinants of health/health-related social needs?
  f. Do you screen for medical or behavioral health needs?
12. Can you describe the ways that people access services through [Hub name]?
  a. Are individuals identified by CBOs?
    i. Do CBOs conduct screenings for Hub service needs? Or how do they identify potential patients or clients?
  b. Do you reach out to people identified by providers or payers?
    i. Do health care partners conduct screenings for Hub service needs?
  c. Can people directly access services through [Hub name]?
13. Once someone has accessed services through [Hub name], how do they interact with it over time?

## Information Technology

14. Can you describe data sharing and referral management between the organizations involved in [Hub name]?
  a. How is data on individual service recipients shared to facilitate care coordination?
    i. What technologies or solutions do you use to facilitate referrals and data sharing?
    ii. Who shares data in this way—which partners?
      1. Probe about CBOs on the one hand and health care partners on the other.
      2. Are there challenges in sharing information in this way?
      3. What successes have you had in information-sharing?
    iii. How do you manage referrals? Do you monitor for closed-loop referrals, and if so, what do you do if you find out that patients are not receiving services they appear to need?
  b. How is data collected on the quality or impact of [Hub name’s] services?
    i. How is this data collected on Hub care coordination activities?
    ii. How is this data collected on CBO services?
    iii. How is this data collected on health care services?
    iv. Are there challenges in collecting and analyzing these data?
    v. Do you monitor or report the quality of services that are provided?
  c. What sources of information does [Hub name] use to and assess population needs or impact?
    i. What kind of data do you collect or have access to related to social determinants of health or health-related social needs and service provision? Does the data identify resource needs?
  d. How is success, both short and long term, defined (e.g., key health and social service outcomes)?
  e. How could policies improve data-sharing efforts for this initiative?
  f. What challenges do you face in collecting data that could help inform the operations of your network?

## Funding Sources

15. How is [Hub name] funded?
  a. How is the core infrastructure of the network funded? Probe for:
    i. Medicare (MA plans/traditional Medicare)
    ii. Medicaid (MCOs/state)
    iii. Other health systems
    iv. Governmental—federal, state, local
      1. Grants support?
      2. Other monetary support?
      3. In-kind or non-monetary support, such as a part-time employee, data analysis, or other support?
  b. How are the CBO-provided services funded? Probe for:
    i. Medicare (MA plans/traditional Medicare)
    ii. Medicaid (MCOs/state)
    iii. Other health systems
    iv. Governmental—federal, state, local
      1. Grants support?
      2. Other monetary support?
      3. In-kind support?
  c. Many organizations combine funds from multiple sources to finance their programs. Does the initiative rely on combining funds from different sources to support its efforts?
    i. Does reimbursement and financing from contracts cover full costs of the Hub services?
      1. If no: How do you cover the additional costs not covered from reimbursement or contract financing?
        a. Probe: volunteers, donations, endowment
  d. How could policy changes improve the financing of the initiative? How are the initiative’s operational coordinating activities and care and social service activities funded?

## Policy

16. What current policies enable [Hub] to partner with health care organizations?
  a. Probe: federal, state, and local policy
  b. Are there specific policy changes that have contributed to the success of [Hub name]?
17. How could policy changes reduce the challenges that [Hub name] faces in addressing patients’ needs?
  a. Probe: federal, state, and local policy
  b. What do you view as the next steps in improving the work of [Hub name] moving forward?
  c. What can be done to increase social service provider capacity and service provision for health-related social needs?
  d. What would make this initiative replicable and/or scalable to other communities, populations, or settings (clinical, geographic, etc.)?