# Appendix A Discussion Guide for Fiscal Year 2022 Project on Hub Organizations

## Oral Consent Statement

The RAND Corporation, a nonprofit research organization, has been contracted by the Office of the Assistant Secretary for Planning and Evaluation (ASPE) to identify approaches to health and social service coordination and successful models of planning and governance to meet the health and social service needs of communities.

As a part of this effort, we are convening groups of key informants that have experience or insights regarding the implementation of innovative approaches to coordinating health and social services like Community Care Hubs and other similar initiatives. We have invited ASPE staff members to join this discussion. We are particularly interested in hearing how changes to federal, state, or local policies could improve the ability of these efforts to address health-related social needs. For instance, we hope to understand where there are challenges and what solutions have been implemented—or what could be done—to address them? Additionally, what are actionable things at the federal level that could help with community-based governance, information-sharing, sustainability, and other aspects of the coordination of health and social services?

We anticipate this discussion will last approximately one hour. Your participation is voluntary, and there are no benefits to you to participating. You can choose not to participate, or to stop participating at any time.

If you choose to participate, the information you share will NOT be kept confidential from ASPE staff members. ASPE staff may be joining this conversation, and we will summarize the information you share with us with ASPE staff. However, the information shared by specific individuals or organizations will not be attributed by name in summary reports or in other materials that may be made public. Would you still like to participate in this discussion? [YES/NO]

Additionally, we would like to record this conversation so that we can be sure to capture your comments accurately. This recording will be used to facilitate our notetaking and will be deleted after the project is completed. Do you consent to recording? [YES/NO]

Do you have any questions before we begin? [YES/NO]

## Discussion Questions: Individuals with Knowledge of Specific Initiatives

1. To begin, can you tell us a bit about [health and social service coordinating initiative name] and your role(s) there?
  a. Can you please tell us more about how your role specifically related to the coordination of health and social services (either individually or as part of a broader network)?
2. Could you please briefly describe [initiative name] in terms of. . .
  a. How and when did the initiative come to be?
  b. Does the initiative have a formal governance structure or operate under a broader governance structure?
  c. What types of organizations are you partnering with?
  d. Does the initiative have formal governmental partners?
  e. What are the initiative’s key functions?
  f. What is the initiative’s geographic reach?
  g. Please specify each of the services/programs that are coordinated.
  h. Describe the population(s) served? What indicators determine the population(s) served?
3. How are federal and state policies or programs currently supporting this initiative?
  a. What are the limitations of these policies or programs?
  b. How could these or other policies/programs better support this initiative?
  c. How does the initiative address health-related social needs?
  d. How does the initiative screen for social determinants of health and/or health-related social needs?
  e. How does the initiative address social determinants of health and/or health-related social needs?
  f. How does the initiative coordinate service provision across partner organizations (including health care providers)?
  g. Are there [state; federal] policies that could help the initiative better identify social health-related social needs and/or coordinate service provision across partner agencies?
  h. [LOWER PRIORITY, IF TIME PERMITS] How did the initiative function during the height of the COVID-19 pandemic?
4. While this project is particularly focused on initiatives like [initiative name], we are also interested in learning about governance efforts established to identify and coordinate broader efforts to address social determinants of health and/or health-related social needs within a community. Such efforts can take multiple forms and incorporate input from various sources.
  a. Is there an entity in your community that engages in broader planning efforts to identify and coordinate efforts to address broader social determinants of health and/or health-related social needs? Can you please describe how this entity functions and how your organization interacts with it?
    i. What was the impetus of the organization?
    ii. Who are the initiative’s leaders and what are their responsibilities?
    iii. Are local/state government agencies involved and how?
    iv. In your opinion, what kinds of activities should the community governance entity undertake in the next year or so to further efforts related to health and social needs care?
    v. Is there anything you would ideally change about how the initiative operates?
  b. [IF COMMUNITY GOVERNANCE OR OTHER ENTITY DOES NOT EXIST]
    i. Without a broader community governance/planning effort in your community, how do you foster collaboration across your network to identify and address health-related social needs?
  c. [LOWER PRIORITY, IF TIME PERMITS]
    i. Who are the stakeholders, including community members, involved in the governance organization? What are their respective roles and responsibilities?
    ii. Do participating initiatives have formal contractual arrangements with the community governance organization, or is participation voluntary?
    iii. How does the initiative assess community needs?
    iv. Are there any federal, state, or local policies that you think could be helpful to advance community governance?
5. Can you describe data sharing between the organizations involved in [initiative name]?
  a. What kind of data do you collect or have access to related to social determinants of health or health-related social needs and service provision? Does the data identify resource needs?
  b. Is data shared across partner organizations, both health and social care providers?
  c. What technologies or solutions do you use to facilitate data sharing?
  d. Based on your experience, what kinds of state or federal policies or resources would help to improve data sharing efforts for this initiative?
  e. How is success, both short and long term, defined (e.g., key health and social service outcomes)?
  f. [LOWER PRIORITY, IF TIME PERMITS] What challenges do you face in collecting data that could help inform the operations of your network?
6. How do you ensure quality service delivery?
7. How is the initiative funded?
  a. How is the core infrastructure of the network funded?
  b. How are the initiative’s operational coordinating activities and care and social service activities funded?
  c. Many organizations combine funds from multiple sources to finance their programs. Does the initiative rely on combining funds from different sources to support its efforts?
    i. [PROBE-IMPORTANT]: What challenges have you faced in trying to combine funds? How have you addressed these challenges?
      1. [IF UNKNOWN] Would you be willing/able to share additional details with us via email about the specific challenges in combining funds?
  d. How could state or federal policy changes and guidance improve the financing of the initiative?
  e. How do you plan to sustain operations of this initiative moving forward?
8. What is the initiative doing to improve health equity?
  a. What underserved groups does this initiative reach?
  b. [LOWER PRIORITY, IF TIME PERMITS] What does the initiative do to make sure it is reaching underserved communities and individuals with the greatest needs?
9. What makes this initiative successful? What do you view as the next steps in improving the work of [initiative name] moving forward? Beyond providing additional direct funding, if there were one or two things you think that the federal government or your state government could do to advance your efforts, what would they be?
  a. What are two or three actions or policies that you think would help to increase social service provider capacity and service provision for health-related social needs?
  b. What would make this initiative replicable and/or scalable to other communities, populations, or settings (clinical, geographic, etc.)?
10. FINAL QUESTIONS, LOWER PRIORITY, IF TIME PERMITS
  a. Is there anything else we haven’t asked that would better help us to understand [initiative name]?
  b. Are you aware of other successful health and social service coordination efforts?
  c. Are there any thought leaders in the field or other individuals that you would recommend we speak to?

## Discussion Questions: Individuals with Broader Knowledge

1. To begin, can you tell me a bit about your professional background, particularly with respect to health and social service initiatives?
  a. We are particularly interested in efforts/initiatives that coordinate services for a broad population or community.
2. Based on your experience, can you describe the top two or three community-based organizations (CBOs) that you think have been particularly successful in coordinating health and social services at a community level to address social needs?
  a. What makes them so successful?
  b. [LOWER PRIORITY, IF TIME PERMITS]
    i. What are their key functions?
    ii. What are their geographic reach?
    iii. How have they been funded?
    iv. What types of health and social services are coordinated?
    v. What populations do they serve?
    vi. How do they coordinate services between health and social service providers?
    vii. What data is collected and shared?
    viii. How are community health and/or health-related social needs identified?
    ix. How are the impacts of the initiatives evaluated?
3. While this project is focusing on CBOs in which a lead entity coordinates network operations (e.g., Community Care Hubs, other bridge organizations), we are also interested in learning about broader community coordination efforts that identify and coordinate efforts to address health and/or health-related social needs. Such efforts are sometimes referred to as community governance and can take multiple forms and incorporate input from various sources.
  a. Based on your experience, what would you say are the top two or three most successful community governance organizations involved in coordinating health and social services to address social needs?
    i. What makes them so successful?
    ii. [PROBE]: How are they structured? What types of organizations are involved? How is community input incorporated?
    iii. [PROBE]: Is there a particular model of community governance that performs well?
    iv. [PROBE]: How are community needs assessed?
    v. [PROBE]: How is data shared between organizations?
    vi. [PROBE]: How are they funded? How is funding sustained?
4. What innovative approaches have communities used to implement these governance structures? How have they been able to overcome the existing barriers and challenges?
5. Based on your experience, do you have recommendations to increase community capacity to provide and coordinate social services?
6. Given where the field is at, what do you think are the next steps to move this work forward
  a. What do you think needs to happen to move this work forward in the next 2–5 years?
7. How could health and social service coordinating initiatives be better supported by federal or state policies or programs?
  a. How can policy levers be improved to increase community capacity to address health related social needs?
  b. What are two – three action items that you would recommend to the federal government to increase progress in social and health care coordination efforts?
8. What can be done to more successfully implement health and social service coordinating initiatives?
  a. What can be done to increase social service provider capacity and service provision for health-related social needs?
  b. What can be done to help replicate and scale successful initiatives in other communities, populations, or settings (clinical, geographic, etc.)?
  c. Other potential solutions?
9. Based on your experience, how could health and social service coordinating initiatives better address issues of health equity? [FINAL QUESTIONS, LOWER PRIORITY, IF TIME PERMITS]
  a. Is there anything else we haven’t asked that would better help us to understand health and social service coordination initiatives?
  b. Are there any thought leaders in the field or other individuals that you would recommend we speak to?