# Abbreviations

AAA: Area Agency on Aging
ACL: Administration for Community Living
ACO: Accountable Care Organization
AHC: Accountable Health Community
ASPE: Office of the Assistant Secretary for Planning and Evaluation
CAAC: Central Alabama Aging Consortium
CBO: community-based organization
CCTP: Community-based Care Transition Program
CDC: Centers for Disease Control and Prevention
CIL: Center for Independent Living
CMS: Centers for Medicare and Medicaid Services
COVID-19: coronavirus disease 2019
CPT: Current Procedural Tenninology
DHAD: Direction Home Akron Canton Area Agency on Aging and Disabilities
EHR: electronic health record
FQHC: federally qualified health center
FY: fiscal year
HCPCS: Healthcare Common Procedure Coding System
HHS: U.S. Department of Health and Human Services
HIPAA: Health Insurance Portability and Accountability Act
HRSN: health-related social need
IT: information technology
MCO: managed care organization
NCQA: National Committee for Quality Assurance
PHI: protected health information
RD: registered dietician
RN: registered nurse
SARCOA: Southern Alabama Regional Council on Aging
SDOH: social determinants of health
SFTP: secure file transfer portal
SNF: skilled nursing facility
VA: Veteran Affairs
VHA: Veterans Health Administration
WNYICC: Western New York Integrated Care Collaborative