# Ownership of Hospitals: An Analysis of Newly-Released Federal Data & A Method for Assessing Common Owners

Data Point

## KEY POINTS

- In December 2022, for the first time, the Centers for Medicare & Medicaid Services (CMS) released a public dataset on the ownership of hospitals that are enrolled in Medicare. This report analyzes this new dataset.
- The new CMS data show that nearly half of the 4,644 Medicare-enrolled hospitals are non-profit (49.2 percent), 36.1 percent are for-profit, and 14.7 percent are government-owned. Relative to skilled nursing facilities (SNFs), hospitals are more likely to be non-profit and government-owned and less likely to be for-profit. Across all ownership types, 54.6 percent are structured as corporations, 26.6 percent as limited liability companies, 2.6 percent as partnerships, and 16.2 percent as “other.”
- Using a new approach to impute ownership relationships and identify ultimate corporate parents, we find that chains with at least three hospitals constitute a majority of hospitals (56.1 percent). Mean bed size is similar between chains (170 beds) and non-chain hospitals (166 beds). Nine chains have at least 50 hospitals each.
- Individuals (as distinct from organizations) have 8.0 percent of the ownership shares of hospitals, in contrast to the much larger ownership share of nearly 50 percent by individuals of SNFs. Individuals disproportionately own more specialty hospitals (e.g., psychiatric) and fewer short-term acute care hospitals.
- The owners of SNFs and of hospitals rarely overlap, whether they be organizational or individual owners.
- Future research using these data on hospital ownership, which can be merged with other datasets on hospital characteristics, can inform discussions of competition and consolidation in health care markets, which may have impacts on health care costs, access to care, and quality.

## BACKGROUND

Hospital markets have become increasingly concentrated (typically fewer and larger hospitals in a geographic area) in the past few decades.^1^ In a recent analysis accompanying an environmental scan conducted by RAND, ASPE reported that the percentage of hospital referral regions (HRRs) that are unconcentrated decreased from 23 percent (71 of 306) in 2008 to 12 percent (38 of 306) in 2019.^2^

Consolidation and limited competition in health care markets can increase prices without any clear benefits to patients in terms of improved health care quality. RAND’s environmental scan finds strong evidence that hospital horizontal consolidation is associated with higher prices paid to providers, while the literature is less conclusive on how consolidation impacts health care quality and patient access.^3^ One key challenge to assessing the impacts of consolidation is the lack of data that identifies and maps ownership relationships.

In April 2022 the Centers for Medicare & Medicaid Services (CMS) publicly released datasets on Medicare-enrolled hospitals and SNFs Change of Ownership, including mergers and acquisitions since 2016.^4^ This was in line with the Administration’s plan to improve transparency, safety, and quality of care in the nation’s hospitals and nursing homes^5^ and the President’s Executive Order on promoting competition.^6^ The release made these data more readily available to the public in support of the transparency initiatives noted above. Researchers, press, monitoring agencies, and other interested stakeholders can identify what types of ownership structures are shaping these markets, how those structures are affecting consolidation and competition, and impacts on prices, affordability, and quality.

To further improve transparency, in December 2022, CMS released data on all Medicare-enrolled hospitals, complementing the prior data release which only included the hospitals that had experienced a recent change of ownership.^7^ This December 2022 release enables users to answer basic questions about the hospital industry, including size of chains, prevalence of individual vs. multiple owners, and co-ownership of hospitals and SNFs. As with the previous release, these files can be merged with other CMS public use files (PUFs) for additional policy analyses. The dataset will be updated monthly.

This report provides an overview of the available data, a brief description of the ownership variables, a methodology for calculating the ownership shares by individuals vs. organizations, and several preliminary analyses to showcase the data and lay the foundation for future analyses.

## DATA AND METHODS

### Data

On December 20, 2022, CMS released four files with information on all hospital owners currently enrolled in Medicare, excluding critical access hospitals.^*^ The four files represent ownership at one point in time (December 2022), without any historical data. Their source is the Provider Enrollment, Chain, and Ownership System (PECOS). Before being paid by Medicare, providers must enroll in Medicare through PECOS, either via a paper enrollment form or on-line.^†^ This “enrollment” is only for Medicare providers and is separate from the enrollment of Medicare beneficiaries.

The hospital file has enrollment data, including hospital name, physical address, and (for merging) CMS Certification Number (CCN). The owner file distinguishes between individuals and organizations and between direct and indirect owners. Unlike a direct owner, there is at least one subsidiary between the provider and an indirect owner. Owners with less than 5% ownership shares need not be reported.

In this report, to enhance our analyses of the hospital enrollment file, we merged it with two public use files (PUFs): Care Compare, which provides information on the number of beds; and hospital cost report, which provides information on urban-rural location. Providers are asked about organizational structure, but currently the enrollment form does not offer “government” as one of the options.^‡^ This information is available in a different data source - Care Compare - as part of the state-agency submitted data, and we used this alternative data source for categorization of government entities in this report.

### Methodology

As the dataset does not have variables for ultimate owners or for chains,^§^ we developed an approach for identifying those variables. An ultimate owner is an entity that has a subsidiary (e.g., a hospital) but which is not a subsidiary of another entity. All individual owners are ultimate owners, because individuals cannot be owned by other individuals or by organizations.

To identify ultimate owners of organizations, we first assume that the owner of the largest set of hospitals is generally the ultimate owner, in part, because all hospitals owned by a subsidiary are also owned by the ultimate owner.^**^ In the second step, any hospitals owned by the first ultimate owner are removed from the working file, and the owner of the most remaining hospitals is arguably a second ultimate owner, and so forth. This methodology identifies hospital chains using only the existing PECOS data. (For details on our methodology, see the appendix.)

### Limitations

The primary limitation of the PECOS data is that it is self-reported. Nonetheless, PECOS is designated as a System of Record (SOR) for Medicare provider enrollment data. That is, if there is a conflict between PECOS and another dataset in CMS, PECOS is considered authoritative for Medicare provider enrollment data.

There are other limitations due to several data issues. First, owners with less than a 5 percent share of a provider are not required to be reported and generally do not appear in the dataset. Second, as noted, the dataset does not identify ultimate owners, which is why we developed a method to infer ultimate owners and hence to assign hospitals to chains. A third set of limitations relates to data errors. While most hospitals (72.0 percent) report having at least one direct and/or indirect owner, ^††^ of these, 216 report indirect owners but not direct ones (a logical inconsistency). For direct owners, the ownership shares are either missing or sum to more than 100 percent (479 and 143 hospitals, respectively) (see Table A-2). All told, 838 hospitals report owners with problematic data, comprising more than one-sixth of all hospitals (838/4,644=18.0 percent).

Finally, there are limitations related to our assignment methodology, which presumes a hierarchical set of subsidiaries. Although such hospitals are the numerically dominant structure (constituting at least three-fifth of hospitals), little is known about the structure of the other two-fifths. In contrast, we do not search for a set of interlocking owners, which are arguably more plausible for individual owners, who are atypical owners of hospitals (See the appendix’s discussion organizational structures.)

We have vetted our assignment methodology in two ways (see appendix). First, using filings with the Security and Exchange Commission (SEC), we vetted the five largest chains, finding that the chains were correctly identified, even if the ultimate owner was not always distinguished from its first-tier subsidiary. Second, we used branding (sometimes incorporated into a hospital’s doing-business-as name) to vet our assignment of hospitals to chains. Some hospitals, however, are branded as part of a specific chain but are not assigned to that chain. Such findings point the way towards an improved dataset of chains.

## RESULTS

### Overview of U.S. Hospitals

Our dataset is comprised of 4,644 hospitals and as noted, does not include critical access hospitals. (See the methodology and data appendix for further details.) As presented in Table 1, short-term acute care hospitals constitute about 70 percent of hospitals and have above-average mean beds. In contrast, specialty hospitals (except for children's hospitals) have below-average mean beds.

Table 1 Hospital Type, Control Type, and Other Features of U.S. Hospitals, 2022

Hospital type | Hospitals | | Mean beds
Hospital type | | | Mean beds
Hospital type | Number | % | Mean beds
Total | 4,644 | 100.0% | 168
Hospital type
Short-term acute care | 3,240 | 69.8% | 198
Psychiatric | 631 | 13.6% | 110
Rehabilitation | 341 | 7.3% | 66
Long-term care | 342 | 7.4% | 65
Children’s | 90 | 1.9% | 241
Control type
Non-profit | 2,286 | 49.2% | 209
For-profit | 1,677 | 36.1% | 107
Government | 681 | 14.7% | 175
Organizational structure
Corporation | 2,534 | 54.6% | 198
Limited liability company (LLC) | 1,237 | 26.6% | 91
Partnership | 121 | 2.6% | 177
Other | 752 | 16.2% | 187
Urban-rural location
Urban | 3,173 | 68.3% | 171
Rural | 1,217 | 26.2% | 161
Missing | 254 | 5.5% | -

Because bed size is missing for 6.6 percent of hospitals, mean beds is calculated without those hospitals.

Sources: PECOS, Care Compare, and cost reports.

Almost half of hospitals are non-profit and they are larger hospitals on average, with a mean bed size of 209 (vs. 107 for for-profit and 175 for government hospitals).

Hospitals structured as corporations constitute 54.6 percent of hospitals and are larger than average by bed size. Limited liability companies (LLCs) constitute 26.6 percent of hospitals and have the smallest size (91 beds on average). Partnerships constitute fewer than 2.6 percent of hospitals. A challenge in interpreting these numbers is that an organization can be both an LLC and a partnership.^‡‡^ A second challenge is that 16.2 percent of hospitals and beds are classified as “others.”

Over two-thirds of hospitals are in urban areas, and they are slightly larger on average than rural hospitals (171 vs. 161 beds). About 5.5 percent of hospitals are missing urban-rural location data.^§§^

PECOS makes a distinction between owners who are individuals and those that are organizations. We estimate that individuals have a total ownership share that equals 8.0 percent of all hospitals.^***^ Organizations have 90.9 percent of hospital ownership shares, with the remaining 1.1 percent representing owners whose shares were below 5 percent and hence who did not need to be reported.

Given that organizational owners numerically dominate, we focus on them in our analyses below.

### Organizational Owners

We have assigned many hospitals to organizations that appear to be their ultimate owners. Hospitals with the same organizational ultimate owner constitute an organizational chain. Some hospitals are not assigned to any owner (either organizational or individuals); presumably most of these have a governing board.

As presented in Table 2, the nine chains with at least 50 hospitals owned 18.1 percent of hospitals and a slightly lower share (15.9 percent) of beds. (There are 730,285 beds reported across all hospitals in this dataset.) If the minimum was defined as five hospitals, chains had slightly less than half of hospitals (48.5 percent) and beds (47.1 percent). If we define the minimum for being a chain as owning three hospitals, chains have a majority of both hospitals (56.1 percent) and beds (56.3 percent). The remaining hospitals are not affiliated with a chain. These non-chain hospitals constitute 43.9 percent of all hospitals. The mean bed size is similar - 170 for chains and 166 for non-chain hospitals.

Table 2 Distribution of Chains, Hospitals, and Beds, by Chain Size, 2022

Chain size (# of hospitals) | number | | | % of hospitals in chains | % of hospitals | % of beds
Chain size (# of hospitals) | | | | % of hospitals in chains | % of hospitals | % of beds
Chain size (# of hospitals) | chains | hospitals | beds | % of hospitals in chains | % of hospitals | % of beds
Total in this table | 243 | 2,603 | 411,385 | 100.0% | 56.1% | 56.3%
50 or more | 9 | 841 | 115,815 | 3.7% | 18.1% | 15.9%
25–49 | 10 | 331 | 51,742 | 4.1% | 7.1% | 7.1%
10–24 | 36 | 509 | 84,088 | 14.8% | 11.0% | 11.5%
7–9 | 42 | 329 | 55,163 | 17.3% | 7.1% | 7.6%
5–6 | 44 | 241 | 44,606 | 18.1% | 5.2% | 6.1%
3–4 | 102 | 352 | 59,971 | 42.0% | 7.6% | 8.2%

The hospital chains with at least 10 hospitals are listed in Table 3. For each chain, the state with a plurality of its hospitals is listed, as is the percentage of its hospitals in that state. Each of the ten largest chains are spread across multiple states and have less than one-third of their hospitals in any single state. Smaller chains are more likely to be limited to one state (or two or three contiguous ones). The ten largest chains are for-profit entities, except for Common spirit, which is a non-profit entity. Smaller chains are more likely to be non-profit. The largest government chain is NYS Office of Mental Health, which is ranked 20^th^, and there are nine governmental chains with between three and nine hospitals each.

Table 3 Hospital Chains With At Least Ten Hospitals, 2022 (In descending order by number of hospitals)

Hospital Chains with At Least Ten Hospitals | | (Listed in declining order by number of hospitals)
Rank | Chain/Ultimate owner | | | State home to greatest % of chain’s hospitals | | Control type
Rank | Chain/Ultimate owner | | | | | Control type
Rank | Chain/Ultimate owner | Count | | State | % of chain’s hospitals in that state | Control type
Rank | Chain/Ultimate owner | | | State | % of chain’s hospitals in that state | Control type
Rank | Chain/Ultimate owner | Hospitals | Beds | State | % of chain’s hospitals in that state | Control type
Total in dataset | | 4,644 | 730,285
Total in this table | | 1,681 | 251,645
These chains as % of total | | 36.2% | 34.5%
1 | HCA, INC. | 152 | 37,353 | FL | 29% | for-profit
2 | UNIVERSAL HEALTH SERVICES INC | 147 | 19,108 | TX | 14% | for-profit
3 | ENCOMPASS HEALTH CORP | 122 | 8,353 | TX | 18% | for-profit
4 | SELECT MEDICAL CORP | 107 | 6,009 | OH | 13% | for-profit
5 | COMMUNITY HEALTH SYSTEMS INC | 74 | 9,929 | IN | 14% | for-profit
6 | LIFEPOINT HEALTH INC | 66 | 6,620 | NC | 12% | for-profit
7 | KNIGHT HEALTH HOLDINGS, LLC | 63 | 5,870 | TX | 19% | for-profit
8 | COMMONSPIRIT HEALTH | 58 | 9,891 | CA | 22% | non-profit
9 | TENET HEALTHCARE CORP | 52 | 12,682 | CA | 25% | for-profit
10 | ACADIA HEALTHCARE COMPANY INC | 47 | 4,344 | LA | 9% | for-profit
11 | TRINITY HEALTH CORP | 44 | 10,091 | MI | 16% | non-profit
12 | KAISER FOUNDATION HOSPITALS | 36 | 9,148 | CA | 97% | non-profit
13 | PRIME HEALTHCARE SERVICES, INC | 31 | 4,686 | CA | 35% | mixed
14 | STEWARD HEALTH CARE SYSTEM LLC | 30 | 5,345 | MA | 23% | for-profit
15 | EPOCH ACQUISITION INC | 30 | 1,006 | TX | 30% | for-profit
16 | BON SECOURS MERCY HEALTH INC | 29 | 5,338 | OH | 48% | non-profit
17 | PAM CUBED LLC | 29 | 1,395 | TX | 28% | for-profit
18 | ADVENTIST HEALTH SYSTEM SUNBELT HEALTHCARE CORP | 28 | 7,174 | FL | 61% | non-profit
19 | ARDENT LEGACY HOLDINGS INC | 27 | 3,215 | TX | 37% | for-profit
20 | NYS OFFICE OF MENTAL HEALTH | 22 | 3,821 | NY | 95% | govt
21 | TEXAS HEALTH RESOURCES | 22 | 2,601 | TX | 100% | mixed
22 | UPMC | 21 | 4,818 | PA | 90% | non-profit
23 | SUTTER HEALTH | 21 | 3,494 | CA | 100% | non-profit
24 | BANNER HEALTH | 21 | 5,244 | AZ | 76% | non-profit
25 | ADVOCATE AURORA HEALTH, INC | 21 | 4,716 | WI | 62% | non-profit
26 | CHRISTUS HEALTH | 19 | 3,621 | TX | 68% | non-profit
27 | IHC HEALTH SERVICES INC | 18 | 2,359 | UT | 78% | non-profit
28 | OCEANS TOPCO, INC | 17 | 553 | LA | 53% | for-profit
29 | QUORUM HEALTH CORP | 16 | 1,363 | IL | 25% | mixed
30 | SPRINGSTONE HEALTH OPCO, LLC | 16 | 1,331 | TX | 31% | for-profit
31 | SIGNATURE HEALTHCARE SERVICES, LLC | 15 | 1,901 | CA | 40% | for-profit
32 | ASCENSION HEALTH | 15 | 2,537 | TN | 40% | non-profit
33 | THE CLEVELAND CLINIC FOUNDATION | 15 | 3,595 | OH | 73% | non-profit
34 | CORNERSTONE HEALTHCARE GROUP HOLDING | 14 | 695 | TX | 36% | for-profit
35 | BAPTIST MEMORIAL HEALTH CARE CORP | 14 | 2,405 | MS | 43% | non-profit
36 | MERCY HEALTH | 13 | 4,120 | MO | 54% | non-profit
37 | BALLAD HEALTH | 13 | 1,756 | TN | 69% | non-profit
38 | CHARLOTTE-MECKLENBURG HOSPITAL AUTHORITY | 13 | 3,626 | NC | 54% | mixed
39 | COVENANT HEALTH | 12 | 1,652 | TN | 75% | non-profit
40 | OCHSNER CLINIC FOUNDATION | 12 | 1,335 | LA | 75% | non-profit
41 | DIGNITY COMMUNITY CARE | 12 | 2,222 | CA | 67% | non-profit
42 | SSM HEALTH CARE CORP | 12 | 2,721 | MO | 58% | non-profit
43 | PRIME HEALTHCARE FOUNDATION INC | 11 | 1,492 | CA | 36% | mixed
44 | SHRINERS HOSPITALS FOR CHILDREN | 11 | - | OH | 9% | non-profit
45 | LHC GROUP, INC | 11 | 340 | LA | 73% | for-profit
46 | NEW YORK CITY HEALTH AND HOSPITALS CORP | 11 | 3,277 | NY | 82% | govt
47 | FRANCISCAN ALLIANCE, INC. | 11 | 1,641 | IN | 91% | non-profit
48 | ASCENSION SETON | 10 | 1,130 | TX | 100% | non-profit
49 | MCLAREN HEALTH CARE CORP | 10 | 1,857 | MI | 90% | non-profit
50 | NORTHWELL HEALTHCARE INC | 10 | 3,723 | NY | 100% | non-profit
51 | BETH ISRAEL LAHEY HEALTH, INC | 10 | 2,245 | MA | 100% | non-profit
52 | MEDSTAR HEALTH, INC | 10 | 2,497 | MD | 70% | non-profit
53 | CHAMBER INC | 10 | 2,228 | CA | 30% | for-profit
54 | SURGERY CENTER HOLDINGS INC | 10 | 291 | TX | 30% | for-profit
55 | VIBRA HEALTHCARE, LLC | 10 | 881 | CA | 40% | for-profit

Notes: Ultimate owners may own subsidiaries but are not subsidiaries of other owners. Because the number of beds is missing for 6 percent of hospitals, care should be taken when using that variable. If fewer than 75 percent of hospitals are of the same control type (for profit/non-profit/govt), “mixed is reported.

Most of the dozen largest hospital chains concentrate in one of the five hospital types, either short-term acute hospitals or one of four types of specialty hospitals. HCA, Community Health, Common spirit, Tenet, Trinity, and Kaiser concentrate in short-term acute hospitals. Universal and Acadia concentrate in psychiatric hospitals, Encompass in rehabilitation hospitals, and Select and Knight in long-term care (LTC) hospitals. LifePoint concentrates less than the other chains.

### Individual Owners

Hospitals in which individuals have a majority of ownership shares constitute 6.9 percent (320/4,644) of hospitals. Individual-owned hospitals are disproportionately specialty hospitals. Individuals have a majority of shares of almost of a quarter (23.8 percent) of psychiatric hospitals (150/631). The same measure is 14.0 percent (48/342) for long-term care hospitals and 10.9 percent (37/341) for rehabilitation hospitals, but 2.6 percent (83/3,240) for short-term acute care hospitals.

Only eight individuals own the equivalent of at least five hospitals.^†††^ As shown in Table 4, the top ranked individual owns at least part of 114 hospitals. This individual owns a total ownership share of 84.2 hospitals, for which they own 74 percent shares on average. At the bottom of the table, the 8^th^ ranked individual owns 100 percent of each of their hospitals. Individuals ranked 1 and 5 concentrate on psychiatric hospitals, and individuals ranked 2, 3, and 4 concentrate on a combination of rehabilitation and long-term care hospitals.

Except for individual ranked 2, each owner’s share averages more than half, suggesting that each owner controls most of their hospitals.

Almost two-thirds of hospitals owned by the individual ranked 4 are in Texas and almost all of those owned by the individual ranked 6 are in Louisiana. Otherwise, the hospitals owned by each individual are not concentrated in a single state.

Table 4 Largest Individual Owners and the Distribution of their Hospitals by Specialty and by State, 2022 (In descending order by number of hospitals)

| | | | | | | | | State home to greatest % of owner’s hospitals
Rank | Count of hospitals owned (perhaps partially) | | | | | | Equivalent # of hospitals, B | Mean ownership share, C=B/A | State | % of owner’s hospitals in that state
Rank | Total, A | Short stay | Psychiatric | Rehabilitation | LTC | Children | Equivalent # of hospitals, B | Mean ownership share, C=B/A | State | % of owner’s hospitals in that state
Total | 226 | 32 | 112 | 34 | 40 | 1 | 147.1 | 65% | NA | NA
1 | 114 | 14 | 98 | | 1 | 1 | 84.2 | 74% | FL | 11%
2 | 39 | | | 23 | 16 | | 11.7 | 30% | TX | 28%
3 | 20 | | | 5 | 15 | | 12.1 | 60% | LA | 15%
4 | 14 | | | 9 | 5 | | 7.6 | 55% | TX | 64%
5 | 13 | | 13 | | | | 11.8 | 91% | TX | 31%
6 | 10 | 8 | 2 | | | | 6.4 | 64% | LA | 90%
7 | 8 | 8 | | | | | 5.3 | 67% | CT | 38%
8 | 8 | 2 | | | 6 | | 8.0 | 100% | CA | 25%

Notes: Total is the sum of the counts across the five hospital types. LTC = long-term care (hospitals).

The equivalent number of hospitals is calculated as the sum of the ownership shares (percentages) divided by 100.

### Common Ownership of Hospitals and SNFs

Because hospital patients can be discharged to SNFs, financial integration of hospitals and SNFs might facilitate clinical integration. For this reason, we searched for evidence that the two provider types were under the same ultimate owners, be it organizational or individual. Out of 14,810 SNFs, only 336 were owned by one of the hospital chains with at least three hospitals each. The two hospital chains with the most SNFs have several times as many as SNFs as hospitals and hence might be best described as SNF chains that own a few hospitals.

Only four individuals owned the equivalent of at least two hospitals and the equivalent of at least two SNFs. While these two analyses are not definitive, in part, because they do not consider what non-chain hospitals might own, the analyses suggest that few organizations or individuals own both hospitals and SNFs.

## CONCLUSION

This report describes several useful patterns that can be gleaned from CMS’s new data released on hospital ownership. This report is intended to familiarize potential users with some of the types of analyses—such as those involving chains, individual owners, and geography—that can be performed with these data in combination with public use files, as well as identify some of the limitations and challenges of using these data.

Organizations own the vast majority of shares of hospitals (90.9%), individuals own 8.0%, with the remaining 1.1% pertaining to owners whose share of a specific hospital is too small to require reporting.

Organizational chains with at least three hospitals constitute a majority of hospitals (56.1 percent). The methodology of assigning hospitals to chains presumes a hierarchical structure, which is the prevalent structure (representing at least three-fifths of hospitals).

A knowledge of chains is important for several reasons. First, it can be supportive of program integrity efforts. If a problem is identified in one hospital within a chain, the problem may be prevalent among other members of that chain. Second, chains may have additional administrative capabilities relative to hospitals that are not members of a chain. Third, knowing chains is necessary for calculating market concentration in local markets. Future analyses merging this dataset with changes of ownership and other datasets on hospital characteristics can be used to inform trends in consolidation and competition that may have important impacts on health care costs, access to care, and quality.

## APPENDIX DATA AND METHODS

### Data

Overview of the Dataset and Definitions: On December 20, 2022, CMS released four files with information on the owners of hospitals currently enrolled in Medicare, as noted.

Hospital file: This hospital-level file has enrollment data, including hospital name, physical address, NPI, and (for merging) CMS Certification Number (CCN).

As noted in the Data Guidance for hospitals, CMS uses “provider” in two senses. For the purpose of ownership, a provider represents a tax identification number (TIN); for the purpose of certification, a provider represents a CMS CCN. We use “provider” in the latter sense.

Each CCN uniquely identifies a hospital. Providers report their TIN when submitting forms to PECOS. Rather than make public these TINs, CMS has uniquely assigned to each TIN an associate ID, which is in this file.

In the typical arrangement, each associate ID represents the legal form of a single CCN. The associate ID may have direct and indirect owners.

The hospital file has 7,272 observations. However, there are several categories of these observations that are excluded from our analysis, as shown in Table A-1. There are 2,305 observations that represent special units within a hospital (i.e., psychiatric units, rehabilitation units, and swing beds). None of these units file cost reports. Because they have the same associate ID as their parent hospital, they have the same owners. Hence, they are excluded here.

Table A-1 Counts of Hospitals by Steps in Database Construction

Count of hospitals
Total | Change | Description
7,272 | | downloaded from data.cms.gov
| (2,305) | Special units within hospitals (e.g., psych beds)
| (259) | ASCs & IFEDs enrolled as hospitals during PHE
| (37) | duplicate CCNs
| (27) | Critical Access Hospitals (CAHs)
| (2,628) | total dropped
4,644 | | working file

Another 259 observations were enrolled as hospitals during the public health emergency (PHE). Almost half of these are ambulatory surgery centers (ASCs), and a slight majority are independent free-standing emergency departments (IFEDs), the latter being almost entirely in Texas.

Because PECOS treats critical access hospitals (CAHs) as a different provider type from other hospitals,^‡‡‡^ they are largely excluded in this initial release of hospital data. (CAHs were first included in the July 2023 release.) However, a few CAHs are included. For simplicity of interpretation, those hospitals are excluded here. Given these exclusions, our working file has 4,644 hospitals.

Owner file: In this hospital-owner-level file, each of hospital’s “owners” is defined by a “role” variable. For the purposes of this report, the more prominent roles are direct owner, indirect owner, partner, officer, and director. Consistent with the standard usage, this report uses “owner” to mean only the first two roles. Unlike a direct owner, there is at least one subsidiary between the provider and an indirect owner. Owners whose ownership shares are less than 5 percent are not required to be reported.

An owner-type variable distinguishes between individuals and organizations. The first two roles (direct owner, indirect owner) can be either type; the last two roles (officer and director) pertain to individuals only. We discuss partners below.

For each direct and indirect owner, the file reports the share of the provider owned by that owner.

Ownership shares of direct owners should not sum to more than 100 percent. For instance, if an organization owns 50 percent of a provider and an individual owns 46 percent, this indicates that there is another owner (or set of owners) that own the remaining 4 percent but do not appear in the dataset, due to the 5 percent threshold on ownership share for reporting.

Ownership shares of indirect owners, however, can sum to more than 100 percent. For example, suppose a provider is 100 percent owned by organization A, which is 100 percent owned by organization B, which is 100 percent owned by organization C. Organization A would be a direct owner and the organizations B and C would be indirect owners. The shares of indirect owners would sum to 200 percent. As noted, the ultimate owner—the owner that is not a subsidiary of another owner—is not identified in PECOS. (As used here, an “ultimate owner” can have a small share of total ownership.) On an organizational chart, the ultimate owner is typically displayed at the top. Individual owners are necessarily ultimate owners, but organizational ultimate owners need to be inferred (see below).

Data on partners requires some explanation. On the one hand, PECOS allows for both organizational and individual partners to be entered. On the other hand, the Internal Revenue Service (IRS) describes a partnership as “the relationship between two or more people to do trade or business.” ^8^ For hospitals, organizations reported as partners have almost seven times the ownership share (87.3 percent) that individual partners have (12.7 percent).^§§§^ The disadvantage of providers listing organizations as ‘partners” instead of as “owners” is that the second tier of control (analogous to indirect owners) is not recorded. So, our approach to inferring the ultimate owner does not work with partnership data.

Fortunately, almost all hospitals that recorded partners also recorded owners (206); only eleven hospitals recorded partners but not owners. When both ownership and partner data are available, we use only owner data.

Table A-2 classifies hospitals by the nature of their ownership data. Of the 4,644 hospitals in the working file, two-thirds (3,344) report either direct or indirect owners in the owner file. Of these, 216 report having indirect but not direct owners, a logical inconsistency. Of those reporting direct owners, 479 reported hospital names but not report the ownership shares. Of those reporting shares, 143 reported shares summing to more than 100 percent. In sum, although 72.0 percent of hospitals reported owners, only 54.0 percent reported owners without data problems.

Table A-2 Hospitals in Working File, by Whether They Have Owners and The Nature of Any Problematic Data

Nature of Ownership Data | # of hospitals | | % of hospitals
Working file of hospitals | 4,644 | | 100.0%
Reported direct &/or indirect owners | 3,344 | | 72.0%
indirect owners only | | 216 | | 4.7%
direct owners
missing owner share | | 479 | | 10.3%
sum of shares >100% | | 143 | | 3.1%
without data problems | | 2,506 | | 54.0%
Reported partners (but not owners) | 11 | | 0.2%
Reported neither owners nor partners | 1,289 | | 27.8%
in chain of at least 3 hospitals | | 191 | | 4.1%
free-standing | | 1,098 | | 23.6%

Notes: The counts of the three data problems are additive. Hospitals without “owners” have an associate ID that may pertain to several other hospitals. PECOS does not call this an “owner,” but it functions as one.

Another 1,289 hospitals (27.8 percent) did not report either an owner or a partner. Although most hospitals have their own associate ID, 191 hospitals reported no owners or partners but shared an associate ID with at least three other hospitals. Here are three prominent examples: Kaiser Foundation Hospitals is a nonprofit with 36 hospitals. Appalachian Regional Healthcare (ARH) is a nonprofit with six hospitals, largely in eastern Kentucky. Health and Human Service Commission, part of the Texas government, has nine psychiatric hospitals. Although PECOS does not use the term “owner” in these cases, each of these three groups are chains (or at least parts of one). The other hospitals not reporting owners or partners are unaffiliated with a chain and presumably have governing boards (or are government owned).

In our database construction, all hospitals that reported no owners are treated as if their associate ID was a direct owner, thus ensuring that these hospitals are included in our subsequent analyses.

Two other released files: The December release includes two other files. The additional-NPI file deals with the fact that a few hospitals have multiple NPIs even though the vast majority of hospitals have only one. This small file is a concise method to present those additional NPIs. (We call this the “NPI file.”)

The final file deals with the fact that hospitals may deliver services in multiple locations. (We call this hospital-address-level file the “address file.”) Although hospitals are defined by their inpatient facilities, the majority of their revenues (across all payors) are now delivered in hospital outpatient departments (HOPD). These services can be delivered on the same campus as the inpatient services, but they can also be delivered in off-campus (HOPD), perhaps miles away.

Even though the off-campus HOPDs often function like physician offices, Medicare typically pays them at higher rates than physician offices. Medicare collects data on payment by whether on or off campus but not by each HOPD location, limiting the analyses one could perform with this file. This brief does not analyze this file.

Other Data: For this report, the hospital file was merged with two other CMS Public Use Files (PUFs): the Care Compare files and Medicare Cost Reports.^9^ Care Compare provides information on number of beds and profit status (i.e., for-profit, non-profit, government).^****^ Hospital cost reports report urban or rural location.^††††^

As discussed at the end of this appendix, when we assign hospitals to chains, the results can be inconsistent with how hospitals present themselves to the public via branding.

### Methodology: Organizational owners and their chains

If the 855A enrollment form identified ultimate owners of each hospital, defining hospitals chains would be relatively straightforward.^‡‡‡‡^ All hospitals with a given ultimate owner would be assigned to same chain, which could be labeled as the owner’s name.^§§§§^

Here is our methodology for assigning hospitals to chains based on their ownership data.

Several stylized organizational structures: The usefulness of our methodology varies by the relationships among a hospital’s owners. To facilitate discussion of ownership structures, we present four stylized structures, which are by no means comprehensive. Org Chart 1 presents a simple hierarchy in which the ultimate owner directly owns the hospital, which has its own tax identification number (TIN). Org Chart 2 presents a simple hierarchy with two tiers of subsidiaries between the ultimate owner and the hospital. That is, the hospital is owned by a second-tier subsidiary, which is owned by a first-tier subsidiary, which is owned by the ultimate owner.^*****^ The ultimate owner and each of the two tiers of subsidiaries own 100 percent of the hospital.

Org Chart 1 Simple Hierarchy without Subsidiaries

Org Chart 2 Simple Hierarchy with Two Tiers of Subsidiaries

Org chart 3 presents a 50–50 joint venture. Unlike the two simple hierarchies, each ultimate owner has a 50 percent ownership share.

Org Chart 3 50–50 Joint Venture

Org Chart 4 Interlocking Ownership

Org Chart 4 presents the most complex of the four structures considered here, namely interlocking owners.^†††††^ Hypothetically, there are two hospitals, each of which has the same three ultimate owners. Owner 1 owns 40 percent of hospital A and 25 percent of hospital B, owner 2 owns 30 percent of hospital A and 25 percent of hospital B, and owner 3 owns 30 percent of hospital A and 50 percent of hospital B. The ownership shares sum to 100 percent for hospital A and 100 percent for hospital B.

Prevalence of types of organizational structures: Estimating the prevalence of the various structures would ideally be based on a mutually exclusive set of categories that make intuitive sense. However, the heterogeneity of structures makes this difficult, and data quality issues exacerbate these problems. Still two simple calculations can be made.

Out of 2,506 hospitals reporting direct owners and without data problems, 1,523 report only owners with 100% shares, implying that each owner constitutes a different tier. These hospitals necessarily have a hierarchical organizational structure, although there may be additional hospitals that also have that structure. Thus, at least 60.8% (1,523/2,506) of hospitals with owners are structured with a hierarchy.

Another 35 hospitals are structured as 50–50 ventures. These hospitals constitute only 1.4% (35/2,506) of hospitals.

We hypothesize that interlocking owners are more common among individual owners than organizational ones, because when many individuals pool their financial resources by forming a corporation, they are better positioned to buy entire hospitals (or other providers). Given that individuals have only 8 percent of ownership shares of hospitals but about half of shares among SNFs, we would expect more interlocking ownership among SNFs. Testing our hypothesis probably requires network analysis.

Assignment Methodology: Our methodology is designed for hierarchical ownership structures, as illustrated in the first two org charts. The methodology is based on this relationship: An ultimate owner ipso facto owns all the hospitals that are owned by each one of its subsidiaries. (If it has multiple first-tier subsidiaries, the ultimate owner may own more hospitals than any one of its subsidiaries.)

To assign hospitals to chains, we first retained all the TINs with an ownership share above 50 percent.^‡‡‡‡‡^ For instance, in Org Chart 2, three TINs were retained. For each TIN in the file (across all hospitals), we obtained a count of the hospitals with that TIN. The TIN with the most hospitals was considered to define a chain, which took the TIN name. After those hospitals were dropped from the working file, the next TIN with the most hospitals was identified and a second chain was delineated. The process continued until all the three-TIN chains were delineated, which was indicated by the delineation of the first two-hospital chain. Once the ultimate owners have been identified, we found that a few hospitals had been assigned to two chains, perhaps because of data anomalies. These issues were resolved by manual review.

If all of the hospitals in a chain have reported both the ultimate owner and its first-tier subsidiary as owners (though the PECOS data does not distinguish those roles), the TIN for those two entities would have the same number of hospitals. If the ultimate owner is not reported (but should be) for at least one hospital in the chain, the first-tier subsidiary TIN would have a higher count of hospitals. In that case, the chain would be correctly delineated even though the associated TIN is not the ultimate owner.

### Spot Checks using SEC Annual Reports

One opportunity for vetting our assignments of hospitals to chains utilizes reports filed with the Security and Exchange Commission (SEC). The ultimate owner of publicly traded firms must file annual reports with the SEC. For the five largest chains in Table 3 (all of which file SEC reports), we compared our data to the SEC ultimate owner, as presented in Table A-3.

Table A-3 Ultimate Owner Based on PECOS Ownership Data vs. SEC Annual Reports, Five Largest Chains, 2022

PECOS ownership data
Chain | | # of hospitals | | ownership %
Rank | Possible ultimate owner | # | % of max | mean | SEC
1 | HCA, INC. | 152 | 100% | 99%
1 | HCA HEALTHCARE INC | 151 | 99% | 99% | SEC
1 | HEALTHTRUST INC. - THE HOSPITAL COMPANY | 145 | 95% | 99%
2 | UNIVERSAL HEALTH SERVICES INC | 151 | 100% | 100% | SEC
3 | ENCOMPASS HEALTH CORPORATION | 122 | 100% | 93% | SEC
3 | ENCOMPASS HEALTH OWNED HOSPITALS HOLDINGS LLC | 69 | 57% | 100%
4 | SELECT MEDICAL CORPORATION | 107 | 100% | 98% | SEC
5 | CHS COMMUNITY HEALTH SYSTEMS INC | 74 | 100% | 100%
5 | COMMUNITY HEALTH SYSTEMS INC | 74 | 100% | 100% | SEC
5 | HMA-TRI HOLDINGS LLC | 60 | 81% | 100%

Notes: For each chain as constructed here, the ultimate owner (per PECOS) is listed first. Of the alternative owners (of the same set of hospitals), only those with a majority of a chain’s hospitals are also listed. The last column indicates the ultimate owner (per SEC annual report, 2022).

To understand the table, consider the three owners of HCA: 152 hospitals were owned by HCA, INC. All but one of them were also owned by HCA Healthcare, and 95% were also owned by Healthtrust (144/152). Each of the three owners had mean ownership shares of 99%. Therefore, consistent with Org Chart 2, two of these were subsidiaries of the ultimate owner, but the question is which owner is the ultimate owner. Our approach selected HCA, Inc, whereas the SEC report indicates it is HCA Healthcare.^§§§§§^ Our methodology does not distinguish between ultimate owner and its first-tier subsidiary, but either one defines the same chain.

Of the next three chains (Universal, Encompass, and Select), our methodology yielded the ultimate owner as reported by SEC. In the fifth chain, two entities owned the same 74 hospitals. Our methodology cannot distinguish between the ultimate owner and its first-tier subsidiary. The SEC report indicates the ultimate owner is Community Health Systems.

Across these five chains, our review of SEC reports confirms that our methodology for assigning hospitals to chains is reasonable.^******^

Conclusion: Our common owner methodology appears insensitive to minor data quality issues in identifying chains that have majority ownership of each of its hospitals, but it is not designed to identify chains involving 50–50 ventures or interlocking ownerships.

### Vetting Chains Using Brand Names

In part because ownership data is self-reported, vetting of our assignment of hospitals to chains is desirable. Vetting might pertain to at least two issues: Which chains (as initially constructed) should be combined? And which hospitals are not assigned to a chain but should be?

Investigations of both issues might start with how each chain has branded its hospitals. PECOS requires providers to report their legal name and has an optional field for reporting their Doing Business As (DBA) name, which are the names they use when interacting with the general public. DBA names often start with the name of the chain. For instance, if a hypothetical chain named “XYZ” owns one hospital in the east section of town and another in the west section, their DBA names might be XYZ East Hospital and XYZ West Hospital. So, a convenient way to find a common brand is to retain the first word (or several words) of each hospital’s name and determine whether multiple hospitals have the same initial name. This approach presumes that hospitals with the same brand are in the same chain. However, not all chains incorporate their brand into the DBA names of their hospitals.

About 550 hospitals (about 13 percent) had names that start with possible brand names. The relationship between these brands and chain is presented in Table A-4, which has counts of hospitals by the combination of brand and chain.^††††††^ Ideally, all of hospitals under each brand would have the same chain, which is true for these three brands: HCA, KINDRED, and TEXAS HEALTH. A number of brands identify a few hospitals that have not been assigned to the chain of a majority of hospitals but possibly should be. For instance, one hospital branded as “KAISER” is not assigned to the Kaiser chain, and six of the hospitals branded “ENCOMPASS” are not assigned to the Encompass, the third largest chain.

Table A-4 Using Brands to Vet Reported Ownership Data

(within a brand, chains are listed in declining order by number of hospitals)

Brand | Chain/Ultimate owner | Number of hospitals
Brand | Chain/Ultimate owner | by brand-chain combination | by brand only
Total in this table | | 562 | NA
ADVENTHEALTH | ADVENTIST HEALTH SYSTEM SUNBELT HEALTHCARE | 28 | 31
ADVENTHEALTH | unassigned to any chain | 3 | 31
ASCENSION | unassigned to any chain | 19 | 53
ASCENSION | ASCENSION HEALTH | 10 | 53
ASCENSION | ASCENSION SETON | 8 | 53
ASCENSION | ASCENSION VIA CHRISTI HEALTH INC | 4 | 53
ASCENSION | ST. VINCENT’S HEALTH SYSTEM, INC. | 4 | 53
ASCENSION | SACRED HEART HEALTH SYSTEM INC | 3 | 53
ASCENSION | COLUMBIA ST MARYS HOSPITAL MILWAUKEE INC | 2 | 53
ASCENSION | ST JOHN PROVIDENCE | 1 | 53
ASCENSION | LIFEPOINT HEALTH INC | 1 | 53
ASCENSION | ST JOHN HEALTH SYSTEMS INC | 1 | 53
BAYLOR SCOTT & WHITE | unassigned to any chain | 15 | 32
BAYLOR SCOTT & WHITE | TEXAS HEALTH VENTURES GROUP LLC | 6 | 32
BAYLOR SCOTT & WHITE | BAYLOR UNIVERSITY MEDICAL CENTER | 5 | 32
BAYLOR SCOTT & WHITE | BAYLOR SCOTT & WHITE MEDICAL CENTERS - CAPITOL AREA | 3 | 32
BAYLOR SCOTT & WHITE | BAYLOR REGIONAL MEDICAL CENTER AT PLANO | 2 | 32
BAYLOR SCOTT & WHITE | SELECT MEDICAL CORPORATION | 1 | 32
BON SECOURS | BON SECOURS MERCY HEALTH INC | 9 | 10
BON SECOURS | BON SECOURS CHARITY HEALTH SYSTEM, INC. | 1 | 10
CHI | COMMONSPIRIT HEALTH | 23 | 27
CHI | unassigned to any chain | 4 | 27
ENCOMPASS | ENCOMPASS HEALTH CORPORATION | 106 | 112
ENCOMPASS | unassigned to any chain | 6 | 112
HCA | HCA, INC. | 47 | 47
KAISER | KAISER FOUNDATION HOSPITALS | 35 | 36
KAISER | unassigned to any chain | 1 | 36
KINDRED | KNIGHT HEALTH HOLDINGS, LLC | 46 | 46
PAM | PAM CUBED LLC | 27 | 41
PAM | PAM SQUARED, LLC | 8 | 41
PAM | POST ACUTE MEDICAL LLC | 5 | 41
PAM | unassigned to any chain | 1 | 41
SELECT | SELECT MEDICAL CORPORATION | 78 | 79
SELECT | unassigned to any chain | 1 | 79
TEXAS HEALTH | TEXAS HEALTH RESOURCES | 21 | 21
UNIVERSITY OF MARYLAND | UNIVERSITY OF MARYLAND MEDICAL SYSTEM CORP | 7 | 9
UNIVERSITY OF MARYLAND | unassigned to any chain | 2 | 9
VIBRA | VIBRA HEALTHCARE II, LLC | 8 | 18
VIBRA | VIBRA HEALTHCARE, LLC | 6 | 18
VIBRA | unassigned to any chain | 2 | 18

Note: Excluded from this table are brands with fewer than seven hospitals.

The brands PAM and VIBRA each have a pair of chains with very similar names, suggesting ownership relationships that is not apparent from the present dataset construction. The PAM brand has PAM CUBED LLC and PAM SQUARED, LLC. The VIBRA brand has VIBRA HEALTHCARE II, LLC and VIBRA HEALTHCARE, LLC.

Finally, two brands each have more than a dozen unassigned hospitals. The ASCENSION brand has 53 hospitals, 19 of which are not assigned to any chain and the remaining are spread over nine chains. The BAYLOR SCOTT & WHITE brand has 32 hospitals, 15 of which are not assigned to any chain and the remaining are spread over four chains.

In the cases of ASCENSION and BAYLOR SCOTT & WHITE, in particular, some of the anomalies may represent legacy ownership relationships that have not been updated. That is, hospitals may have updated their names but not all of their owners.^‡‡‡‡‡‡^

Once plausibly incomplete data has been identified, additional information might resolve the issue. Non-profit entities must submit IRS form 990 to the Internal Revenue Service. The forms are downloadable, although they may not list each hospital. But there is no analogous data source for for-profit entities. Some chains list their hospitals on their website.^§§§§§§^

Because many hospital names do not start with the brand name, this approach cannot be applied to a majority of hospitals in chains. However, the problems found in these brands plausibly occur in other chains.

### Methodology: Individual owners

Although PECOS does not identify ultimate owners, all individual owners are ultimate owners, because individuals cannot be owned by other individuals or by organizations. We leverage this fact to calculate the percentage of hospitals (or more precisely, the percentage of ownership shares) owned by individuals.

Consider hypothetical provider X reporting three direct owners: one individual A with 25 percent ownership share and two organizations with 35 percent and 40 percent shares, respectively. Each of the two organizational owners are owned by another entity. The 35 percent organization is owned by an individual B (35 percent), and the 40 percent organization is owned by an organization (40 percent). Therefore, individuals own 60 percent of provider X (25 percent+35 percent). Summing direct ownership shares and indirect ownership shares (both of individuals) does not involve double counting, because all individual owners are ultimate owners.

An additional complexity is that owners with shares below 5 percent need not be reported. In such cases, we do not know whether owners are individuals or organizations. However, the unreported share can be calculated as 100 percent minus the sum of the shares of [underlined: direct] owners, because those shares should not exceed 100 percent. The share of organizational owners is, therefore, 100 percent minus the sum of individual shares (direct + indirect) and minus the sum of unreported shares (direct only).^*******^ If 3 percent of ownership shares were unreported, 37 percent of provider X would be owned by organizations (that is, 100 percent - 60 percent -3 percent). Included in our calculation of individual ownership shares as a percentage of all hospitals are hospitals that are partnerships (completely owned by individuals) and hospitals without any direct or indirect owners. (The latter hospitals are implicitly owned by organizations.)

## REFERENCES

1 Vogt William B. "Hospital market consolidation: trends and consequences." Expert Voices (2009). Fulton, Brent D. Health Care Market Concentration Trends In The United States: Evidence And Policy Responses. Health Affairs 2017 36:9, 1530–1538
2 Liu Jodi L., Environmental Scan on Consolidation Trends and Impacts in Health Care Markets. RAND, 2022. Environmental Scan on Consolidation Trends and Impacts in Health Care Markets (hhs.gov)
3 Ibid.
4 https://data.cms.gov/provider-characteristics/hospitals-and-other-facilities/hospital-change-of-ownership. See also Welch W.P., Ruhter J., Bosworth A., De Lew N., and Sommers B.D. Changes of Ownership of Hospital and Skilled Nursing Facilities: An Analysis of Newly-Released CMS Data (Issue Brief No. HP-2022–14). Office of the Assistant Secretary for Planning and Evaluation, U.S. Department of Health and Human Services. April 2022. https://www.aspe.hhs.gov/reports/changes-ownership-hospital-skilled-nursing-facilities, accessed 11-26-22.
5 https://www.whitehouse.gov/briefing-room/statements-releases/2022/02/28/fact-sheet-protecting-seniors-and-people-with-disabilities-by-improving-safety-and-quality-of-care-in-the-nations-nursing-homes/
6 https://www.whitehouse.gov/briefing-room/presidential-actions/2021/07/09/executive-order-on-promoting-competition-in-the-american-economy/
7 https://www.cms.gov/newsroom/press-releases/biden-harris-administration-continues-unprecedented-efforts-increase-ownership-transparency-health
8 IRS, “Tax Information For Partnerships,” https://www.irs.gov/businesses/partnerships, accessed 3-10-23.
9 https://data.cms.gov/provider-data/topics/hospitals, accessed 12-13-22.

* The four files are as follows: A hospital-level file (“Hospital_Enrollments”), a hospital-owner-level file (“Hospital_All_Owners”), a hospital-addresses-level file (“Hospital Additional Addresses”), and a (very small) file of hospitals with multiple NPIs (“Hospital_Additional_NPIs”). https://data.cms.gov/provider-characteristics/hospitals-and-other-facilities/hospital-all-owners, https://data.cms.gov/provider-characteristics/hospitals-and-other-facilities/hospital-all-owners, accessed on 12–21-22. Scroll down to find related data files and data guidance.

† Hospitals and other institutional providers enroll using form 855A, which can be found at: https://www.cms.gov/medicare/cms-forms/cms-forms/downloads/cms855a.pdf, accessed 3-10-23.

‡ Medicare Enrollment Application – Institutional Providers, CMS 855A, p. 11, accessed 3–29-23.

§ The enrollment form has a section on chains, but the data are not included in the data release

** Only owners with a majority share of a hospital are included here.

†† Hospitals that do not have owners (or partners) are presumed to have a governing board.

‡‡ IRS, “Publication 3402 (03/2020), Taxation of Limited Liability Companies,” https://www.irs.gov/publications/p3402, accessed 3–9-2023.

§§ PECOS contains each hospital’s physical address, which could be used to impute urban-rural location.

*** That is, of individual owners of hospitals, few own entire hospitals; rather they own shares of certain hospitals. Those ownership shares sum to 8% of all hospitals. See the end of appendix for the methodology of dividing ownership into three components: individuals, organizations, and unreported.

††† The equivalent number of hospitals is calculated as the sum of the ownership shares (percentages) divided by 100. For instance, if an individual owns 80 percent of each of three hospitals, their equivalent number of hospitals would be 2.4 hospitals.

‡‡‡ CAHs have no more than 25 beds and are paid 101% of their costs.

§§§ The mean ownership share of organizational partners is 25% but only 2% for individual partners.

**** Prior to merging, the CCN in the hospital file required modification, the most important modification is inserting a leading 0 and minor one is dropping suffixes. The vast majority of observations in the hospital file merged.

†††† The percentage of hospitals that merge depends, in part, on the currency of the cost report. Our data included only reports for fiscal years ending in 2019.

‡‡‡‡ The SNF ownership release has an “affiliated entity” variable; the hospital release does not.

§§§§ For simplicity, assume that each ultimate owner has a 100% ownership share.

***** The ownership data does not indicate which TIN is the ultimate owner, which is the first-tier owner, and so forth.

††††† A related term is “interlocking directorates,” where individuals serve on the boards of competing firms. In the case of medical providers (e.g., nursing homes), members of a family (i.e., people related by marriage or blood) might jointly own a number of hospitals, even if many hospitals lack a majority owner.]

‡‡‡‡‡ To avoid dropping too many hospitals, owners that did not report shares were also considered.

§§§§§ The introduction to the report mentioned both entities (and no other).

****** As Table 3 shows, many hospital chains are nonprofit. As such, they are required to submit IRS Form 990, which includes information on “related organizations.” ProPublica has recently made such filings more accessible via its “Nonprofit Explorer: Research Tax-Exempt Organizations.” https://projects.propublica.org/nonprofits/, accessed 6–12-23. This issue brief has largely completed when this new data source was publicized. As yet, we have not investigated it.

†††††† Of hospitals with same ultimate owner, some might be branded and some not. HCA, the largest chain, has 152 hospitals (see Table 3) but only 47 have the brand and hence are reported in Table A-3.

‡‡‡‡‡‡ Change of ownership must be reported within 30 days of the effective date.

§§§§§§ For instance, in our dataset, PRIME HEALTHCARE SERVICES, INC and PRIME HEALTHCARE FOUNDATION INC have 31 and 11 hospitals, respectively. Prime Healthcare lists its 45 hospitals, https://www.primehealthcare.com/Print.aspx?Page=%2fOur-Locations.aspx, accessed 2–26-23. Presumably one could crosswalk the on-line list of names and addresses and our dataset.

******* Even this may be an overestimate because some unreported direct owners may be owned by a reported indirect owner.