# Generic Drug Utilization and Spending Among Medicare Part D Enrollees in 2022

Issue Brief

In 2022, 43.3 million Medicare Part D enrollees (82 percent) filled 1.1 billion prescriptions for generic prescription drugs. While most enrollees filled at least one prescription for $2 or less, most (54 percent) also paid more than $2 for at least one generic drug. Over 6 million enrollees (12 percent) filled at least one generic prescription for over $20. A standardized formulary of high-value generics that cost beneficiaries $2 or less in out-of-pocket spending would reduce confusion and help enrollees afford their prescription drugs.

## KEY POINTS

- Medicare Part D enrollees had 1.1 billion prescriptions for generic drugs, accounting for nearly 2 billion 30-day equivalent prescriptions, $5.7 billion in patient out-of-pocket (OOP costs), and $32.9 billion in gross drug costs.
- If all fills for generics had been filled at $2 or less for a 30-day supply, total OOP would have been $1.6 billion – a reduction of $4.1 billion or around 71 percent.
- 43.3 million of the 53.1 million Medicare Part D enrollees (82 percent) filled at least one prescription for a generic drug. Of these, 28.6 million (54 percent) had at least one generic fill with OOP costs greater than $2. Nearly 6.5 million enrollees (over 12 percent) had at least one generic fill with OOP greater than $20.
- In total, 70.5 percent of all 30-day equivalents were filled for $2 or less.
- There was large variation in cost-sharing across even the most commonly used generic drugs. While average OOP spending for a common high cholesterol treatment, atorvastatin, was less than $2, nearly 30 percent of 30-day equivalent prescriptions cost more than $2 for enrollees.
- Five drugs among the 20 generics most commonly used by Medicare enrollees (clopidogrel bisulfate, gabapentin, pantoprazole sodium, metoprolol succinate, and omeprazole) had over 40 percent of 30-day equivalent prescriptions with OOP costs greater than $2.
- Of the 20 most commonly used drugs, nine had average OOP greater than $2.
- While generic dispensing rates were similar among Low-Income Subsidy (LIS) and non-LIS enrollees, LIS enrollees paid substantially less in OOP for generic drugs ($0.59) than non-LIS enrollees ($4.00) on average.
- Enrollees in Medicare Advantage Prescription Drug Plans (MA-PDs) were more likely to fill at least one generic drug (87.7 percent) than enrollees in standalone Part D plans (PDPs) (82.7 percent) or those with employer plans (EGWPs) (59.3 percent). MA-PD enrollees also had lower annual OOP spending on generic drugs ($98) than PDP ($163) or EGWP enrollees ($181).
- Among non-LIS enrollees, those in MA-PD plans had the lowest average OOP burden per 30-day equivalent ($4.49), after adjusting for differences in generic drug use and other factors.

## BACKGROUND

Generic drugs are a critical part of the U.S. strategy for achieving value in prescription drug utilization, improving health outcomes, and promoting competition in health care markets. The Drug Price Competition and Patent Term Restoration Act of 1984 (commonly known as the Hatch-Waxman Amendments) established various exclusivity periods for branded small-molecule prescription drugs and a 180-day generic drug exclusivity period for the first manufacturer to submit a certification for patent invalidation. ^1^ After losing patent protection and/or exclusivity, generic versions of branded drugs may enter the market, creating competition for the initial drug. Existing research has overwhelmingly found that when generic drugs enter the market, prices fall substantially, with prices falling as low as 30 percent of the brand price just three years after entry, with more generic entrants further lowering the price. ^2–6^ These price reductions have the potential to result in savings for the health care system and reductions in patient out-of-pocket (OOP) costs. ^4^ Generic drug dispensing in the United States across all prescription drugs (including those without generic alternatives) stands at 80 percent of dispensing, ^7^ and at over 90 percent in the Part D program. ^8^

While gross prices fall for drugs after generic entry, recent evidence suggests that only some of the potential savings from generic competition are passed on to patients in terms of reduced OOP costs. Some studies have found that at least some generic drugs have seen increases in price and OOP costs for patients, ^9^ with other work finding that even among generic drugs with competition, price reductions are not fully passed along to patients. ^10^ A more recent study found that generic prices often substantially exceeded acquisition costs, resulting in higher OOP payments than would otherwise be expected. ^11^ Thus, while generic drugs play a vital role in improving access to medications, there may be market dynamics that limit the extent to which patients can fully take advantage of these benefits.^*^ These dynamics may lead to variation in how generic drugs are covered and priced for patients across Part D plans, leading to use of potentially more expensive and/or less effective drugs as well as reduced adherence.

Medicare enrollees might avoid taking prescribed medications due to limited price transparency and affordability. ^12–14^ Indeed, though most Part D plans include small copayments for generic drugs, copayments are not standardized and can vary by plan. ^15^ The addition of other insurance design features such as preferred versus non-preferred tiering, coinsurance versus copayments, prior authorization, step therapy requirements, and quantity limits makes filling a prescription even more complex. The result is that enrollees often do not know the price they are paying^16^ until they are at the pharmacy counter.^†^ Providers face similar challenges as patients because they are often unable to determine the most cost-effective drug for their patients, even though they may want to consider patient cost burden in their clinical decisions. ^17^

Addressing these issues is critical to ensuring that Medicare enrollees can achieve the maximum health benefit from effective therapies. There is strong, consistent evidence finding a relationship between OOP cost and patient adherence to medications. ^18–21^ And in some settings, value-based insurance designs that either substantially lower or eliminate the copayment for a high-value drug (such as drugs used to treat common chronic conditions) have been shown to increase take-up of the drug. ^22–25^ Improved adherence is likely to lead to better outcomes for patients, a higher quality of life, and potentially lower utilization of medical treatments. ^26,27^ If price reductions due to generic entry or other dynamics are passed along to patients in the form of lower OOP cost (e.g., through lower copayments), these price reductions are likely to increase the use of the generic drug, improving both adherence to the therapy and health outcomes.

While there are also non-cost barriers to care, these aspects of the generic drug market present opportunities for Part D improvements that reduce OOP cost sharing for certain prescription drugs. On October 14, 2022, President Biden issued an executive order directing the Secretary of the Department of Health and Human Services (HHS) to consider testing models aimed at improving prescription drug affordability and access for Medicare and Medicaid enrollees through the Center for Medicare and Medicaid Innovation (CMMI). ^28^ In response to the executive order, HHS issued a report outlining three models geared towards improving the use and development of high-value drugs. ^29^ As noted in the report, one of these models, the Medicare $2 Drug List (M2DL) Model, would create a high-value generic drug list that Medicare Part D prescription drug plan sponsors could offer enrollees at a low, fixed copayment (up to $2 for a month’s supply) without restrictions such as step therapy, prior authorization, or quantity limits.

With the M2DL model in development, ^30^ the purpose of this Issue Brief is to understand the scope of generic drug utilization at baseline and reflect on the potential impact this model could have on making generic drugs more accessible and more affordable to Medicare beneficiaries with Part D coverage.^‡^ We document the landscape of generic drug spending among Part D enrollees in 2022, focusing on OOP spending. One objective of the model would be to make OOP payments at the pharmacy more transparent and predictable to both the Medicare enrollee and the prescribing physician. Variation in OOP payments across and within drugs can occur due to differences in drug prices and Part D Plan formulary designs. In this paper, we detail the variation of OOP costs across generic drugs used by enrollees as well as the variation in OOP costs for specific drugs, both of which may occur due to these factors. Additionally, we address differences in OOP costs and generic utilization rates for Medicare enrollees overall, and how they differ across demographic characteristics, low-income subsidy [LIS] enrollment,^§^ and plan characteristics.

## METHODS

We relied on the 2022 Part D prescription drug event (PDE) file to identify utilization of all prescription drugs with a generic alternative available. We focused on drugs with at least 300 prescriptions (to ensure adequate volume), and that had a marketed generic and an approved Abbreviated New Drug Application (ANDA).^**^ Enrollee characteristics were drawn from the Master Beneficiary Summary File (MBSF). Enrollee OOP payment was defined as the patient pay amount from PDE data, regardless of formulary status. LIS status was defined based on whether the enrollee was ever enrolled in the LIS program within the year.

All costs were calculated after the enrollee reached their respective deductible. We focused on the post-deductible phase for each enrollee because the OOP payment determined by coinsurance or copayments, which has been shown to affect prescription drug utilization, takes effect in this phase. ^31,32^ Additionally, because utilization post-deductible is more likely to capture the copayments or coinsurance required by plans, it is more comparable to a $2 or less standardized formulary considered under the M2DL. Where a generic drug is covered through a copayment or coinsurance (by waiving the deductible), these instances are included as long as the PDE was listed with a post-deductible phase. Straddle claims (those that cross phases) are also included.

Prescription drugs were categorized into pharmaceutically equivalent products (PEPs) using the Medi-Span Generic Product Identifier. This classification system classifies drugs into a unique combination of dosage, dosage form, and active ingredient. We then collapsed PEPs into their underlying active ingredient, aggregating over different dosing forms and strengths. When referring to drugs, we are referring to the active ingredient that may represent a combination of drugs.

To identify enrollee plan type, we used a hierarchy based on the number of months enrolled in a particular plan type. This assigned enrollees to the plan type they were enrolled in for the most months. Included plan types were Employer group-waiver plans (EGWP), Medicare Advantage plans with prescription drug benefits (MA-PD), and standalone prescription drug plans (PDPs). Program of All-Inclusive Care for the Elderly (PACE) plans were excluded because they have very low enrollment, cannot charge cost-sharing, and serve a very specific population.

Enrollee rurality was identified based on the enrollee’s zip code and county of residence. This was mapped to a core-based statistical area (CBSA), which is in turn classified as Rural-Micropolitan or Urban-Metropolitan. Valid zip code and county combinations without a categorization were categorized as Rural-Other. Zip code and county combinations which cannot be located in zip code data (e.g. they are located outside of the U.S., or are populated with invalid values) are marked as ”Unclassified.” ^33^

When referring to enrollees, estimates are at the annual level. When referring to individual drugs, estimated averages and distributions are based on individual fills. In addition, we calculated 30-day equivalent supply to account for plan design and enrollee preference that could lead to differences in days supplied. We calculated 30-day equivalents by calculating total days supplied and dividing by 30.^††^ Thus, a supply of less than 30 days was treated as a partial 30-day supply. Except where otherwise noted, all analyses are presented restricted to generic prescriptions and exclude the brand-name prescriptions.

In the last section we present adjusted estimates of OOP spending. We performed this adjustment through a linear regression of OOP for a 30-day equivalent on the following variables: plan type, the type of pharmacy filling the prescription, and enrollee rurality. All variables were also interacted with LIS status to account for differential use of drugs and enrollment by plan type and by LIS status. Additionally, this regression included PEP fixed effects to account for differences in drug mix, dosage, and form of the drug. Analytic weights for total number of 30-day equivalents were applied to ensure that results are nationally-representative. This adjustment accounts for differences in drug mix used by enrollees, the plan types in which they enroll, the rurality of where they live, and other factors that may affect how much enrollees pay in out-of-pocket costs.

## FINDINGS

### Generic Drug Utilization and OOP Costs

The majority of Part D enrollees – 43.3 million of 53.1 million total enrollees (81.6 percent) – filled at least one prescription for a generic drug in 2022. In that year, there were nearly 1.2 billion fills for drugs with generic alternatives. Over one billion of these (94.6 percent) were for the generic version, accounting for nearly 2 billion 30-day equivalents.^‡‡^ This indicates that prescriptions were often filled for more than a 30-day supply.

Among fills for generic versions, enrollee spending reached $5.7 billion in patient out-of-pocket (OOP) payments and $32.9 billion in gross drug costs (GDCs).^§§^ While 73.1 percent (38.8 million enrollees) of Part D enrollees filled at least one prescription for $2 or less, more than half (28.6 million) filled at least one prescription for more than $2. In total, 70.5 percent of all 30-day equivalents were filled for $2 or less. If all fill for generic drugs had been filled at $2 or less for a 30-day supply, total OOP would have been $1.6 billion – a reduction of $4.1 billion or around 71 percent.

The high rate of fills for $2 or less is consistent with existing work finding that median copays in the Part D program were $0 for preferred generics in 2022. For other generics, median copays ranged from $5 to $10. ^34^

### Plan Type and LIS Status

Many enrollees qualify for the low-income subsidy LIS benefit (over 25 percent). Due to the financial protections provided by this benefit, LIS enrollees paid less OOP for drugs than non-LIS enrollees. As shown in Figure 1, those receiving LIS benefits filled over 94 percent of 30-day equivalents for $2 or less, compared to just under 60 percent for those without LIS benefits. While filling a prescription for more than $20 was rare among LIS enrollees, 2.4 percent of 30-day equivalents for generics were filled for more than $20 by non-LIS enrollees. In 2022, Full LIS enrollees had copayments limited to $3.95 for generic drugs, and Partial LIS enrollees had coinsurance limited to 15 percent. ^35^

Figure 1 Cost-Sharing Distributions for Generic Drugs by LIS and Non-LIS Enrollees

Note: Percentages reflect the share of 30-day equivalents falling into each cost-sharing category. Restricted to generic formulations. LIS: low-income subsidy.

Figure 1 shows the cost-sharing distributions for generic drugs by LIS and Non-LIS employees.

Based on their choice between Medicare Advantage and the Traditional Medicare (TM) program, and the availability of employee retirement plans for some individuals, Part D enrollees may receive coverage from MA-PDs, PDPs, or EGWPs. These plan types may vary in drug coverage and formulary design.

We identified differences in OOP burden and generic utilization by plan type. MA-PD enrollees were more likely to fill at least one generic and had lower OOP costs per generic fill, regardless of LIS status. This could be due to differences in enrollee characteristics and preferences, or potentially because MA-PD plans are also responsible for enrollees’ Medicare Parts A and B costs, which could incentivize the plans to improve access to and promote the use of prescription drugs to reduce high-cost health service use in other settings. ^36^ MA-PD plans can also use rebate dollars to buy down Part D supplemental premiums, thereby offering richer benefits for the same premium amount. While MA-PD enrollees (87.7 percent of enrollees) were somewhat more likely than PDP enrollees (82.7 percent of enrollees) to use at least one generic drug, enrollees in EGWPs filled at least one generic at a much lower rate (59.3 percent of enrollees).^***^

In addition to differences in generic utilization, there were large differences in OOP burden faced by enrollees in different plan types. MA-PD enrollees were the most likely to fill a 30-day equivalents for $2 or less (80.4 percent of 30-day equivalents), while EGWP enrollees were the least likely (39 percent of 30-day equivalents) (Figure 2).

Figure 2 Cost-Sharing Distributions for Generic Drugs by Plan Type

Note: Percentages reflect the share of 30-day equivalents falling into each cost-sharing category. Restricted to generic formulations. EGWP: Employer Group Waiver Plan. MA-PD: Medicare Advantage Prescription Drug Plan. PDP: Standalone Prescription Drug Plan.

Figure 2 shows the cost-sharing distribution for generic drugs by plan type.

Average OOP costs varied in a similar way across plan types. On average, EGWP enrollees tended to pay the most for 30-day equivalents ($4.34), while MA-PD enrollees paid the least ($2.09). Average OOP costs per 30-day equivalent were $4.00 for non-LIS enrollees and $0.59 for LIS enrollees. (Table 1)

Because the share of enrollees with LIS varies by plan type (for instance, as shown in Table 1, LIS enrollees tend to be under-represented in EGWP plans), observed variation in cost burden across plan types may be driven partly by differences in enrollment of LIS enrollees. However, this did not substantively affect the observed cost distribution (Figure A1) or the costs faced by enrollees on average. (Table 1) Overall, these findings were consistent with prior work finding that MA-PD plans are more likely to include covered generics on the lowest cost-sharing tiers than PDPs. ^37^

Table 1 Average Generic OOP by Plan Type & LIS Status

LIS Status | Plan Type | Average OOP Per 30-Day Equivalent | Total Enrollment (% of Part D)
All | EGWP | $4.34 | 7,867,959 (14.8%)
All | MA-PD | $2.09 | 25,073,192 (47.2%)
All | PDP | $3.72 | 20,142,234 (37.9%)
LIS | EGWP | $0.88 | 139,465 (0.3%)
LIS | MA-PD | $0.52 | 8,585,438 (16.2%)
LIS | PDP | $0.71 | 6,068,432 (11.4%)
Non-LIS | EGWP | $4.44 | 7,728,494 (14.6%)
Non-LIS | MA-PD | $3.03 | 16,487,754 (31.1%)
Non-LIS | PDP | $5.09 | 14,055,802 (26.5%)

Note: 30-day equivalent includes only generic formulation. Generic dispensing rate calculation excludes a small number of fills with an unknown brand/generic designation. LIS: low-income subsidy. EGWP: Employer Group Waiver Plan. MA-PD: Medicare Advantage Prescription Drug Plan. PDP: Standalone Prescription Drug Plan. OOP: out-of-pocket cost. Overall average OOP costs per 30-day equivalent were $2.92; for LIS enrollees they were $0.59; for non-LIS enrollees they were $4.00.

We found little variation in the share of 30-day equivalents filled as generics (the generic dispensing rate) by LIS status. The generic dispensing rate varied from 93.4 percent among non-LIS enrollees in EGWP plans to 95.8 percent among non-LIS enrollees in MA-PD plans. For LIS enrollees, the generic dispensing rate was highest in MA-PD plans (95.2 percent) and lowest in PDPs (94.3 percent).

Overall, these results indicate plan choice and LIS status affects OOP burden, with enrollees in MA-PD plans spending the least in average OOP costs.

### Rurality

Existing evidence suggests that individuals living in rural areas as compared to urban areas may have different health needs and potentially have worse access to care.^†††^ Lack of access to nearby retail pharmacies may in turn lead to differential use of mail order pharmacies, ^38^ which may affect OOP spending and generic drug utilization. If mail order pharmacies offered lower cost-sharing and were disproportionately used by rural enrollees, this could reduce the cost burden of these drugs.

Consistent with the evidence suggesting different health care needs and access to care among the rural population, enrollees in rural areas were the least likely (68.1 percent of fills for micropolitan areas and 66.2 percent of fills for all other rural areas) to fill a 30-day equivalent for $2 or less (Figure 3). While LIS enrollment could affect the likelihood of filling a 30-day equivalent for $2 or less, these findings also held when the sample was restricted to non-LIS enrollees (Figure A2), suggesting that there are other factors playing a role.

Figure 3 Cost-Sharing Distributions for Generic Drugs by Rurality

Note: Percentages reflect the share of 30-day equivalents falling into each cost-sharing category. Restricted to generic formulations. Rural definitions are based on core-based statistical area (CBSA) definition. Rural-All Other: These are all other areas with valid Zip codes that are neither Micropolitan nor Metropolitan. Rural-Micropolitan: These are regions with an urban area that has more than 10,000 but fewer than 50,000 residents. Urban-Metropolitan: These are regions with an urban area that has more than 50,000 residents. Excludes areas with invalid Zip codes.

Figure 3 shows cost-sharing distributions for generic drugs by rurality.

These differences in cost-sharing distribution likely contributed to slight differences in OOP burden by rurality. In general, rural enrollees paid more in OOP for a 30-day equivalent than those in urban areas (Table 2).

Table 2 OOP Costs by Rurality

Plan Type | OOP Per 30-Day Equivalent | Total 30-Day Equivalents (%)
Rural – All Other | $3.17 | 141,392,290 (7.5%)
Rural – Micropolitan | $3.03 | 197,469,217 (10.4%)
Urban – Metropolitan | $2.89 | 1,558,123,256 (82.1%)

Notes: Excludes areas with invalid Zip codes. OOP: out-of-pocket cost.

Surprisingly, we found little difference in the use of mail order pharmacies by rurality. Urban enrollees used mail order pharmacies at a rate similar (14.3 percent) to those in micropolitan areas (14.0 percent) and all other rural areas (14.4 percent).

Variation in OOP burden for generic drugs among the rural population tended to be somewhat higher than elsewhere, and rural enrollees were the least likely to obtain prescriptions for $2 or less. These results were consistent even when accounting for differences in drug mix, LIS status, and other characteristics.

### Variation in OOP Payments for the Most Commonly Filled Drugs

Figure 4 shows that the distribution of generic drug utilization is highly concentrated. The top 20 generic drugs, ranked by number of fills in 2022, accounted for 988.7 million 30-day equivalents (roughly half of all drugs with a generic alternative) and $1.4 billion in OOP spending by enrollees.^‡‡‡^ The top 30 drugs represented nearly 60 percent of 30-day equivalents, and the top 100 drugs represented 86 percent of 30-day equivalents.

Figure 4 Concentration of Generic Drug 30-Day Equivalents, by Volume of Fills

Notes: Restricted to generic formulation. Calculation is the number of 30-day equivalents for drugs falling into a given grouping divided by total generic drug 30-day equivalents.

Figure 4 shows concentration of generic drugs in 30 equivalents by volume of fills.

Because LIS enrollees receive additional protection from OOP costs, LIS enrollees tended to have substantially lower OOP spending and improved adherence to prescription drugs. ^39–42^ Among LIS enrollees, all of the top 20 drugs had average OOP less than one dollar (Table A2), while OOP was significantly higher for the non-LIS population. Because of these low costs for LIS enrollees, we primarily focus on the non-LIS population.

Among the most commonly filled drugs, atorvastatin, a drug for high cholesterol, was the most prescribed generic drug at 97.5 million 30-day equivalents and $128.7 million in OOP spending in 2022. OOP costs for the top 20 drugs varied. The least expensive (in terms of average OOP cost) among the top 20 drugs was hydrochlorothiazide, a treatment for high blood pressure, at an average OOP of $0.74 per 30-day equivalent. The most expensive was gabapentin, a common anti-seizure and nerve pain medication, at an average OOP of $4.64 for a 30-day equivalent (Table 3). The 20 most commonly filled drugs treat some of the most common chronic conditions in the Medicare population including hypercholesterolemia (63.5 percent among TM enrollees), diabetes (26.5 percent among TM enrollees), and hypertension (66.3 percent among TM enrollees). ^43^ Similarly, the top 100 drugs by volume were often treatments for common conditions such as hypertension and hypercholesterolemia. (Table A3)

While the majority (71.2 percent) of these drugs were filled for $2 or less for a 30-day equivalent, there was nonetheless some variation both between and within drugs. For instance, metoprolol succinate was the least likely to be filled at $2 or less (49.6 percent) while hydrochlorothiazide was the most likely (89.3 percent). Of the top 20 drugs, nine had average OOP greater than $2. Even atorvastatin, a drug that has been available as a generic for over a decade, had over 20 percent of 30-day equivalents filled for more than $2. (Table 4) While rankings differed by plan type, the most commonly filled drugs were similar for EGWPs, PDPs, and MA-PD plans. Notably, and consistent with evidence in previous sections, EGWPs tended to have higher OOP burdens. Among non-LIS EGWP enrollees, 13 out of 20 drugs had more than half of their 30-day equivalents filled for more than $2 (Tables A4–A6).

Table 3 Average OOP Costs of Top 20 Prescription Drugs by Volume, Non-LIS, 2022

Active Ingredient | 30-Day Equivalents | % of 30-Day Equivalents | | | | | Average OOP | Examples of Condition(s) Treated
Active Ingredient | 30-Day Equivalents | <=$2 | $2–$5 | $5–$10 | $10–$20 | >$20 | Average OOP | Examples of Condition(s) Treated
Total | 708,350,639 | 71.2% | 19.1% | 7.5% | 2.1% | 0.1% | $1.41
Atorvastatin Calcium | 97,468,006 | 78.3% | 15.6% | 4.9% | 1.2% | <0.1% | $1.32 | Hypercholesterolemia
Amlodipine Besylate | 65,627,233 | 83.7% | 12.6% | 3.0% | 0.7% | <0.1% | $1.04 | Hypertension
Lisinopril | 53,449,406 | 84.4% | 12.1% | 2.9% | 0.6% | <0.1% | $0.97 | Hypertension
Losartan Potassium | 49,077,622 | 75.0% | 18.2% | 5.4% | 1.3% | <0.1% | $1.45 | Hypertension
Metformin HCl | 46,983,504 | 83.0% | 13.1% | 3.1% | 0.7% | <0.1% | $1.06 | Diabetes
Metoprolol Succinate | 42,578,596 | 49.6% | 31.6% | 14.9% | 3.8% | <0.1% | $3.08 | Hypertension, Angina, Heart Failure
Rosuvastatin Calcium | 36,203,975 | 60.7% | 24.3% | 10.6% | 3.7% | <0.1% | $2.71 | Hypercholesterolemia
Omeprazole | 34,589,726 | 59.3% | 23.0% | 14.2% | 3.5% | <0.1% | $2.62 | Gastroesophageal reflux disease
Levothyroxine Sodium | 31,339,492 | 63.9% | 19.7% | 12.5% | 3.8% | <0.1% | $2.40 | Hypothyroidism
Hydrochlorothiazide | 29,279,403 | 89.3% | 9.1% | 1.5% | 0.1% | <0.1% | $0.74 | Hypertension, edema
Simvastatin | 28,488,955 | 84.3% | 11.7% | 3.3% | 0.7% | <0.1% | $1.00 | Hypercholesterolemia
Gabapentin | 26,360,201 | 39.7% | 29.2% | 21.6% | 8.1% | 1.4% | $4.64 | Seizures, nerve pain
Tamsulosin HCl | 26,115,684 | 46.4% | 33.9% | 15.2% | 4.5% | <0.1% | $3.26 | Benign prostatic hyperplasia
Pantoprazole Sodium | 25,844,011 | 52.3% | 31.3% | 12.4% | 4.0% | <0.1% | $2.91 | Gastroesophageal reflux disease
Furosemide | 24,340,816 | 79.6% | 17.3% | 2.8% | 0.3% | <0.1% | $1.16 | Heart failure, edema
Metoprolol Tartrate | 22,495,207 | 80.3% | 15.3% | 3.5% | 0.8% | <0.1% | $1.16 | Hypertension, angina, heart Failure
Carvedilol | 19,660,186 | 70.9% | 21.9% | 5.5% | 1.7% | <0.1% | $1.68 | Heart failure, hypertension
Clopidogrel Bisulfate | 17,100,209 | 55.3% | 26.1% | 13.7% | 4.8% | <0.1% | $2.91 | Coronary artery disease, stroke prevention
Pravastatin Sodium | 16,446,742 | 67.1% | 20.9% | 9.8% | 2.1% | <0.1% | $2.03 | Hypercholesterolemia
Sertraline HCl | 14,901,664 | 70.1% | 20.7% | 7.5% | 1.7% | <0.1% | $1.78 | Depression, obsessive-compulsive disorder, posttraumatic stress disorder

Note: Restricted to generic formulations for non-LIS enrollees. Ranked by total generic 30-day equivalents. OOP: out-of-pocket cost. LIS: low-income subsidy.

### Utilization and OOP Spending for Most Commonly Used Drugs by LIS Status and Race/Ethnicity

The most commonly filled drugs by LIS enrollees were similar to those filled by non-LIS enrollees, all of which treat chronic conditions that are common in the Medicare population. Two drugs appear in the top 20 list for LIS enrollees that do not appear for non-LIS enrollees. These were montelukast, a treatment for asthma, and trazodone, a treatment for depression and insomnia. The two drugs that appear in the top 20 list for non-LIS but not for LIS were clopidogrel, a blood thinner, and pravastatin, a treatment for high cholesterol. (Table A2)

We further investigated variation in the most commonly filled drugs by race and ethnicity. While most drugs in the top 20 for all Part D enrollees were also in the top 20 for each racial and ethnic group, some were not. For instance, sertraline (a treatment for mental health conditions) was ranked 39 for Asian enrollees and 44 for Black enrollees. This may be partly a function of differential rates of diagnosis and lower rates of mental health access (potentially due to cultural differences and/or stigma) for these groups of enrollees, underscoring the importance of non-cost barriers to care. ^44^ Notably, no other selective serotonin reuptake inhibitors were among the most commonly filled drugs for Black or Asian enrollees (Table 4).

To investigate whether there were potentially burdensome OOP payments that varied by patient characteristics, we also calculated average OOP for 30-day equivalents by race and ethnicity. Our results suggested that there did not appear to be disproportionate OOP burden for enrollees of color for the most part. However, American Indian/Alaska Native enrollees tended to have higher OOP than other enrollees for a number of drugs including atorvastatin, amlodipine, gabapentin, and several other drugs (Table 4).

Table 4 Representation and OOP for the 20 Most Utilized Generic Drugs by Race & Ethnicity, Non-LIS, 2022

Drug | Overall | White | | Asian | | Black | | Hispanic | | American Indian/Alaska Native | | Other
Drug | Rank | Rank | Average OOP | Rank | Average OOP | Rank | Average OOP | Rank | Average OOP | Rank | Average OOP | Rank | Average OOP
Atorvastatin Calcium | 1 | 1 | $1.40 | 1 | $0.91 | 2 | $1.20 | 1 | $0.73 | 1 | $2.34 | 1 | $1.20
Amlodipine Besylate | 2 | 2 | $1.11 | 2 | $0.74 | 1 | $0.91 | 3 | $0.63 | 3 | $1.67 | 2 | $0.92
Lisinopril | 3 | 3 | $1.02 | 5 | $0.68 | 6 | $0.85 | 5 | $0.55 | 2 | $1.61 | 4 | $0.89
Losartan Potassium | 4 | 4 | $1.56 | 4 | $0.97 | 4 | $1.30 | 4 | $0.74 | 5 | $2.71 | 5 | $1.32
Metformin HCl | 5 | 5 | $1.14 | 3 | $0.80 | 3 | $0.92 | 2 | $0.63 | 4 | $2.53 | 3 | $1.04
Metoprolol Succinate | 6 | 6 | $3.21 | 7 | $2.53 | 7 | $2.56 | 7 | $1.69 | 8 | $3.70 | 7 | $3.04
Rosuvastatin Calcium | 7 | 7 | $2.90 | 6 | $1.88 | 8 | $1.87 | 6 | $1.27 | 9 | $6.24 | 6 | $2.79
Omeprazole | 8 | 8 | $2.67 | 11 | $2.34 | 11 | $2.56 | 10 | $1.84 | 6 | $4.99 | 11 | $2.47
Levothyroxine Sodium | 9 | 9 | $2.47 | 10 | $2.22 | 23 | $2.04 | 11 | $1.64 | 19 | $2.84 | 12 | $2.31
Hydrochlorothiazide | 10 | 10 | $0.77 | 12 | $0.63 | 5 | $0.65 | 13 | $0.46 | 11 | $1.30 | 10 | $0.70
Simvastatin | 11 | 11 | $1.07 | 8 | $0.68 | 15 | $0.88 | 9 | $0.46 | 12 | $2.44 | 9 | $0.91
Gabapentin | 12 | 12 | $4.91 | 21 | $3.99 | 12 | $4.21 | 8 | $2.32 | 7 | $6.21 | 14 | $4.48
Tamsulosin HCl | 13 | 13 | $3.42 | 9 | $2.70 | 14 | $2.75 | 12 | $1.96 | 14 | $3.08 | 8 | $3.34
Pantoprazole Sodium | 14 | 14 | $3.05 | 15 | $2.42 | 13 | $2.25 | 14 | $1.62 | 13 | $4.69 | 13 | $2.89
Furosemide | 15 | 15 | $1.20 | 25 | $0.98 | 10 | $1.02 | 18 | $0.68 | 10 | $1.80 | 18 | $1.05
Metoprolol Tartrate | 16 | 16 | $1.21 | 17 | $0.84 | 16 | $1.04 | 17 | $0.70 | 17 | $1.77 | 15 | $1.02
Carvedilol | 17 | 17 | $1.76 | 18 | $1.33 | 9 | $1.5 | 16 | $0.98 | 15 | $3.01 | 17 | $1.60
Clopidogrel Bisulfate | 18 | 18 | $3.01 | 22 | $2.74 | 19 | $2.73 | 19 | $1.89 | 18 | $4.94 | 20 | $2.82
Pravastatin Sodium | 19 | 19 | $2.12 | 20 | $1.76 | 17 | $1.62 | 23 | $1.31 | 24 | $2.92 | 19 | $1.99
Sertraline HCl | 20 | 20 | $1.84 | 39 | $1.72 | 44 | $1.60 | 24 | $1.03 | 22 | $1.99 | 24 | $1.66

Note: Restricted to generic formulation and non-LIS enrollment. LIS: low-income subsidy. OOP: out-of-pocket cost. Asian includes Pacific Islanders.

In addition to understanding the average OOP cost for the most commonly filled drugs by race and ethnicity, it is helpful to measure the share of 30-day equivalents filled by non-LIS enrollees for less than $2. As shown in Table 5, we found that for White enrollees, less than half of all 30-day equivalents for simvastatin and gabapentin were filled for $2 or less. Distributions were similar for Asian and Black enrollees, and there were no drugs with fewer than half of 30-day equivalents filled for $2 or less by Hispanic enrollees. As with OOP burden, we found that American Indian/Alaska Native enrollees filled fewer drugs for $2 or less – seven out of the 20 most commonly filled drugs had fewer than half of 30-day equivalents filled for $2 or less.

Table 5 Share of 30-day Equivalents Filled for $2 or Less, Top 20 Drugs, Non-LIS, by Race and Ethnicity

Drug | White | Asian | Black | Hispanic | American Indian/Alaska Native | Other
Atorvastatin Calcium | 82.7% | 87.9% | 85.0% | 89.7% | 70.9% | 85.8%
Amlodipine Besylate | 83.9% | 88.3% | 85.4% | 91.0% | 72.5% | 85.9%
Lisinopril | 73.5% | 81.3% | 76.5% | 86.7% | 59.0% | 76.7%
Losartan Potassium | 81.9% | 86.6% | 84.3% | 89.5% | 65.2% | 83.3%
Metformin HCl | 47.6% | 55.3% | 58.2% | 71.5% | 48.1% | 48.8%
Metoprolol Succinate | 58.2% | 71.0% | 70.4% | 80.7% | 51.2% | 59.5%
Rosuvastatin Calcium | 58.6% | 59.7% | 59.3% | 69.4% | 45.0% | 60.8%
Omeprazole | 63.3% | 62.1% | 66.2% | 71.9% | 57.6% | 64.8%
Levothyroxine Sodium | 89.0% | 89.3% | 89.6% | 92.8% | 73.9% | 90.2%
Hydrochlorothiazide | 83.3% | 88.4% | 85.8% | 92.6% | 67.9% | 85.9%
Simvastatin | 36.6% | 43.6% | 43.9% | 67.5% | 33.3% | 39.6%
Gabapentin | 44.3% | 51.5% | 53.1% | 65.1% | 49.7% | 43.6%
Tamsulosin HCl | 50.2% | 57.3% | 61.0% | 71.8% | 45.2% | 51.4%
Pantoprazole Sodium | 79.0% | 81.6% | 81.1% | 87.4% | 66.6% | 81.8%
Furosemide | 79.8% | 84.0% | 80.8% | 87.0% | 70.0% | 82.5%
Metoprolol Tartrate | 69.9% | 75.6% | 71.5% | 81.9% | 57.7% | 72.5%
Carvedilol | 53.8% | 56.4% | 58.4% | 71.6% | 44.4% | 55.4%
Clopidogrel Bisulfate | 65.9% | 69.5% | 72.6% | 78.1% | 61.3% | 67.9%
Pravastatin Sodium | 69.5% | 68.0% | 70.1% | 80.5% | 65.7% | 72.1%
Sertraline HCl | 55.7% | 65.8% | 62.5% | 78.4% | 49.1% | 58.9%

Note: Restricted to generic formulations and non-LIS population. LIS: low-income subsidy. Asian includes Pacific Islanders.

We further explored variations in affordability of less commonly filled drugs by race and ethnicity. Our analysis found that in some instances, individuals from racial and ethnic groups that have been the focus of health equity concerns accounted for a disproportionate share of all 30-day equivalents of certain drugs. A number of these drugs had a particularly high OOP cost burden.

To identify potential affordability concerns even among prescriptions with relatively less utilization, but where the drug may still be a recommended treatment for common conditions, we focused on prescription drugs with more than 100,000 30-day equivalents supplied in total. We limited our results to at most three drugs and focused on the non-LIS population, for whom high OOP costs may be a significant burden. Our analysis identified several potential affordability concerns.

Black enrollees, for instance, accounted for a disproportionate share of 30-day equivalents for several commonly used anti-hypertension drugs:

- Olmesartan: Black enrollees filled 25.4 percent of 30-day equivalents with average OOP at $7.42. Black enrollees filled 52.0 percent of 30-day equivalents for more than $2 and 6.7 percent for more than $20.
- Nifedipine: Black enrollees filled 23.0 percent of 30-day equivalents with average OOP at $8.14. Black enrollees filled 71.9 percent of 30-day equivalents for more than $2 and 7.0 percent of 30-day equivalents for more than $20.
- Amlodipine combined with olmesartan: Black enrollees filled 21.1 percent of 30-day equivalents with average OOP at $6.60. Black enrollees filled 51.6 percent of 30-day equivalents for more than $2 and 9.3 percent of 30-day equivalents for more than $20.

Asian enrollees accounted for a disproportionate share of two drugs for different conditions:

- Acarbose: A treatment for type 2 diabetes mellitus. Asian enrollees accounted for 11.3 percent of 30-day equivalents with average OOP at $4.54. Asian enrollees filled 47.8 percent of 30-day equivalents for more than $2 and 3.2 percent of 30-day equivalents for more than $20.
- Azelastine: An anti-allergy treatment. Asian enrollees accounted for 11.3 percent of 30-day equivalents with average OOP at $7.29. Asian enrollees filled 51.7 percent of 30-day equivalents for more than $2 and 10.9 percent of 30-day equivalents for more than $20.

Hispanic enrollees accounted for a disproportionate share of several drugs treating various conditions:

- Galantamine: A treatment for dementia. Hispanic enrollees accounted for 19.5 percent of 30-day equivalents with average OOP at $4.71. Hispanic enrollees filled 18.3 percent of 30-day equivalents for more than $2 and 7.9 percent of 30-day equivalents for more than $20.
- Clotrimazole with betamethasone: An anti-fungal treatment. Hispanic enrollees accounted for 19.1 percent of 30-day equivalents with average OOP at $5.99. Hispanic enrollees filled 31.9 percent of 30-day equivalents for more than $2 and 7.3 percent of 30-day equivalents for more than $20.
- Diclofenac (Topical): A treatment for arthritis. Hispanic enrollees filled 16.2 percent of 30-day equivalents with average OOP at $8.95. Hispanic enrollees filled 48.5 percent of 30-day equivalents for more than $2 and 9.3 percent of 30-day equivalents for more than $20.

Lastly, American Indian/Alaska Native enrollees disproportionately filled a drug for opioid use disorder and chronic pain, buprenorphine, with average OOP at $15.41. Nearly 90 percent of 30-day equivalents were for OOP more than $2 and 14.8 percent were for OOP greater than $20.

### Prescriptions Drugs with The Highest Average OOP

To identify commonly used drugs that have high OOP burden, we also examined the top 20 drugs when ranked by average OOP spending. Table 6 shows the distribution of OOP spending and the average OOP burden for 30-day equivalents of these drugs. We restricted this analysis to drugs with more than one million 30-day equivalents. We used a higher threshold than for the analysis in the previous section to ensure that these are widely used therapies across all enrollees. This list includes drugs used to treat other common conditions including asthma, pain, and hypertension. Fewer than one-fifth of these drugs were filled for $2 or less for a 30-day equivalent.

Table 6 Top 20 Generic Drugs by Average OOP, Non-LIS, 2022

Active Ingredient | 30-Day Equivalents | % of 30-Day Equivalents | | | | | Average OOP | Examples of Condition(s) Treated
Active Ingredient | 30-Day Equivalents | <=$2 | $2–$5 | $5–$10 | $10–$20 | >$20 | Average OOP | Examples of Condition(s) Treated
Total | 40,318,730 | 17.7% | 20.3% | 22.5% | 17.2% | 22.3% | $16.19
Fluticasone-Salmeterol | 1,419,769 | 14.9% | 16.3% | 17.4% | 7.6% | 43.8% | $24.60 | Asthma, COPD
Ranolazine | 1,015,786 | 11.5% | 13.9% | 18.8% | 15.3% | 40.5% | $22.99 | Angina
Doxycycline Hyclate | 1,334,051 | 13.7% | 22.8% | 26.4% | 18.0% | 19.1% | $22.44 | Infections
Amoxicillin & Potassium Clavulanate | 1,014,893 | 17.3% | 33.3% | 33.0% | 16.0% | 0.4% | $20.92 | Infections
Nebivolol HCl | 1,425,961 | 11.2% | 15.2% | 20.4% | 16.3% | 37.0% | $19.57 | Hypertension
Oxycodone w/ Acetaminophen | 2,250,695 | 9.9% | 18.9% | 21.1% | 18.9% | 31.2% | $19.26 | Moderate to severe pain
Estradiol (Vaginal) | 2,360,451 | 13.7% | 18.3% | 22.5% | 14.0% | 31.5% | $18.08 | Vaginal symptoms of menopause
Valacyclovir HCl | 1,363,148 | 15.8% | 21.8% | 20.9% | 16.9% | 24.7% | $17.68 | Shingles, cold sores, herpes
Hydrocodone-Acetaminophen | 5,319,491 | 9.0% | 19.9% | 21.1% | 23.9% | 26.1% | $17.13 | Moderate to severe pain
Diclofenac Sodium (Topical) | 1,144,705 | 21.6% | 18.9% | 22.7% | 19.8% | 17.1% | $16.50 | Arthritis
Albuterol Sulfate | 2,578,604 | 22.6% | 11.2% | 24.7% | 21.8% | 19.8% | $15.24 | Asthma, COPD
Azithromycin | 1,193,997 | 40.4% | 30.7% | 21.0% | 7.6% | 0.4% | $15.02 | Infections
Oxycodone HCl | 1,730,232 | 12.1% | 22.2% | 24.9% | 22.4% | 18.3% | $15.00 | Moderate to severe pain
Aripiprazole | 1,165,925 | 20.4% | 22.7% | 21.6% | 22.5% | 12.7% | $14.66 | Schizophrenia, bipolar disorder
Solifenacin Succinate | 1,168,186 | 19.5% | 21.4% | 22.0% | 12.6% | 24.5% | $14.42 | Overactive bladder
Azelastine HCl | 1,554,541 | 15.8% | 19.5% | 20.9% | 20.3% | 23.4% | $13.90 | Seasonal allergic rhinitis
Memantine HCl | 4,004,173 | 23.2% | 17.3% | 23.9% | 16.8% | 18.9% | $13.57 | Dementia due to Alzheimer’s Disease
Pregabalin | 3,034,346 | 17.2% | 22.3% | 23.6% | 16.2% | 20.7% | $12.75 | Epilepsy, nerve pain
Celecoxib | 3,767,271 | 21.9% | 22.3% | 21.9% | 13.1% | 20.8% | $12.19 | Mild-to-moderate pain
Cephalexin | 1,472,505 | 37.9% | 32.2% | 22.2% | 7.5% | 0.2% | $12.07 | Infections

Note: Restricted to generic formulations, non-LIS, and drugs with 1,000,000 or more generic 30-day equivalents. OOP: out-of-pocket cost. LIS: low-income subsidy.

### Variation Among Drugs with Substantial Branded Share

While the majority of drugs in our analysis had very high generic dispensing rates, there were some drugs that had maintained a substantial brand share, even with the availability of generic substitutes. Many of the drugs with lower generic shares have similar OOP payments between the brand and generic versions. In some cases, the generic OOP is higher than that of the brand. Restricting the sample to drugs with 100,000 or more 30-day equivalents, we found that 48 unique drugs had a brand fill rate of more than 30 percent. For 17 of these drugs, the average OOP for the branded version was less than the average OOP for the generic version. In many cases, even if the generic OOP was less than the brand OOP, these differences were small. For instance, the average generic OOP for bepotastine, a treatment for conjunctivitis, was $4.17 while the average brand OOP was $4.36.

Notably, as shown in Table 7, certain commonly used therapies were among those with high brand share: albuterol sulfate (a first-line treatment for asthma), for instance, had a brand share of nearly 62.3 percent, with an average generic OOP of $7.66. Sucralfate, a treatment for duodenal ulcers had a brand share of 37.8 percent and average generic OOP of $6.31.

Taken together, these results indicate the large variation in OOP costs and generic utilization even within drugs and the potential for the M2DL to save enrollees money and shift utilization from brand to generic formulations. Moreover, this underscores how formulary differences, as well as the role of patient assistance programs and advertising can lead to different utilization choices and can affect enrollee OOP in unexpected ways.

Table 7 Volume and OOP of Drugs With Substantial Brand Share

Drug | Brand Share | Average OOP | | % 30-Day Equivalents <=$2
Drug | Brand Share | Brand | Generic | Brand | Generic
Dexlansoprazole | 99.7% | $22.64 | $13.24 | 54.0% | 56.8%
Tafluprost | 99.5% | $47.34 | $29.98 | 19.1% | 26.9%
Trimethoprim | 98.6% | $5.46 | $6.11 | 37.6% | 36.3%
Cyclosporine (Ophthalmic) | 97.4% | $31.86 | $20.80 | 43.2% | 37.2%
Dabigatran Etexilate Mesylate | 96.2% | $46.73 | $43.08 | 20.4% | 32.8%
Brimonidine Tartrate-Timolol Maleate | 92.4% | $26.20 | $23.00 | 35.7% | 32.2%
Lenalidomide | 90.5% | $804.68 | $504.40 | 23.5% | 28.1%
Roflumilast | 89.7% | $29.05 | $10.03 | 44.2% | 62.3%
Icosapent Ethyl | 76.0% | $16.72 | $20.69 | 62.2% | 47.0%
Fesoterodine Fumarate | 74.7% | $31.98 | $13.16 | 37.5% | 44.4%
Brinzolamide | 74.4% | $25.83 | $20.73 | 38.5% | 35.9%
Bepotastine Besilate | 73.9% | $4.36 | $4.17 | 83.2% | 86.2%
Vilazodone HCl | 69.3% | $31.39 | $14.83 | 41.9% | 53.4%
Medroxyprogesterone Acetate | 65.8% | $0.64 | $0.66 | 95.9% | 96.1%
Sulfasalazine | 63.4% | $5.12 | $4.52 | 44.0% | 47.4%
Albuterol Sulfate | 62.3% | $9.48 | $7.66 | 51.6% | 55.1%
Amiloride HCl | 61.6% | $3.32 | $4.00 | 51.6% | 42.6%
Fluticasone-Salmeterol | 60.8% | $25.10 | $16.91 | 42.4% | 39.4%
Epinephrine (Anaphylaxis) | 55.8% | $31.12 | $34.91 | 42.3% | 44.1%
Difluprednate | 53.5% | $33.31 | $26.73 | 31.5% | 30.4%
Candesartan Cilexetil-Hydrochlorothiazide | 53.2% | $6.12 | $4.39 | 66.6% | 72.7%
Levothyroxine Sodium | 51.9% | $3.59 | $1.88 | 68.8% | 72.6%
Glatiramer Acetate | 51.5% | $214.98 | $212.90 | 44.3% | 47.5%
Silver Sulfadiazine | 48.4% | $5.61 | $4.21 | 53.6% | 64.1%
Buprenorphine | 47.3% | $37.39 | $36.46 | 40.1% | 39.0%
Loteprednol Etabonate | 47.0% | $29.90 | $28.65 | 28.7% | 28.2%
Lacosamide | 45.9% | $32.56 | $10.69 | 64.5% | 73.2%
Tretinoin | 45.2% | $11.54 | $12.77 | 40.5% | 45.3%
Naloxone HCl | 44.9% | $27.96 | $28.81 | 54.8% | 50.8%
Diltiazem HCl Extended Release Beads | 44.5% | $5.44 | $5.22 | 42.8% | 39.0%
Fluvoxamine Maleate | 41.5% | $4.31 | $6.80 | 72.0% | 62.2%
Hydrocortisone | 41.0% | $6.37 | $8.31 | 51.7% | 42.4%
Ciprofloxacin HCl (Ophthalmic) | 40.7% | $8.31 | $7.69 | 42.2% | 42.7%
Atropine Sulfate (Ophthalmic) | 40.1% | $10.70 | $10.77 | 53.6% | 49.0%
Benazepril & Hydrochlorothiazide | 40.0% | $2.49 | $2.54 | 69.5% | 71.8%
Nitrofurantoin Macrocrystals | 39.7% | $13.93 | $13.02 | 35.0% | 34.3%
Dimethyl Fumarate | 38.8% | $121.19 | $72.21 | 69.7% | 50.5%
Colestipol HCl | 38.6% | $14.98 | $15.57 | 32.2% | 33.8%
Nitrofurantoin Monohydrate Macrocrystals | 38.4% | $30.27 | $25.89 | 34.2% | 33.1%
Sucralfate | 37.8% | $6.93 | $6.31 | 56.4% | 60.7%
Azelastine HCl-Fluticasone Propionate | 35.7% | $23.35 | $19.92 | 24.4% | 27.8%
Rivastigmine | 35.2% | $28.82 | $29.23 | 46.4% | 42.3%
Cabergoline | 34.9% | $11.20 | $12.71 | 42.3% | 41.0%
Cevimeline HCl | 34.0% | $23.42 | $21.15 | 33.0% | 30.3%
Hydromorphone HCl | 32.6% | $5.66 | $9.02 | 51.1% | 43.6%
Budesonide | 32.5% | $29.74 | $39.04 | 22.3% | 25.2%
Pilocarpine HCl | 30.7% | $9.96 | $9.84 | 46.3% | 37.5%
Calcium Acetate (Phosphate Binder) | 30.5% | $6.08 | $6.65 | 69.2% | 64.1%

Note: Includes both brand and generic formulations. OOP: out-of-pocket cost.

### Adjusted Results: Plan Type, LIS, Rurality, and Pharmacy Type

In previous sections, we documented substantial variation in OOP costs for generic prescription drugs across a number of dimensions. We observed variation was due to differences in LIS status, drug mix, plan type, rurality, and the pharmacy type filling the drug. These differences were partly responsible for variation in OOP burdens by race and ethnicity. In this section, we present results that adjust for these factors.

After accounting for these factors, results on plan type changed somewhat. Non-LIS EGWP and MA-PD enrollees tended to face lower OOP per 30-day equivalent, while non-LIS PDP enrollees faced the highest ($6.42) (Figure 5). This result suggests that OOP protections afforded by PDPs tend to be less generous than other plan types. LIS enrollees still faced very small OOP costs.

Figure 5 Adjusted OOP per Fill for Generic Drugs by LIS and Non-LIS Enrollees and by Plan Type

Note: Average OOP reflects average patient pay per 30-day equivalent. Restricted to generic formulations. Results from a linear regression with average OOP per 30-day equivalent as the outcome and controls for LIS indicator, plan type, pharmacy type, race and ethnicity, rurality, and interactions between LIS and each other variable. Regression included PEP fixed effects and was weighted by the number of fills. OOP: out-of-pocket cost. LIS: low-income subsidy. EGWP: Employer Group Waiver Plans. MA-PD: Medicare Advantage Prescription Drug Plans. PDP: Standalone Prescription Drug Plans. OOP: out-of-pocket cost. LIS: low-income subsidy.

Figure 5 shows out of pocket expense per fill for generic drugs by LIS and Non-LIS enrollees and by plan type.

Unlike the results on plan type, adjusted OOP levels by rurality were similar to the unadjusted results. While enrollees living in urban areas had less in OOP costs ($3.34) than rural enrollees, these differences were small and consistent with unadjusted estimates (Figure 6).

Figure 6 Adjusted OOP per Fill for Generic Drugs by Rurality

Note: Average OOP reflects average patient pay per 30-day equivalent. Restricted to generic formulations. Results from a linear regression with average OOP per 30-day equivalent as the outcome and controls for LIS indicator, plan type, pharmacy type, rurality, and interactions between LIS and each other variable. Regression included PEP fixed effects and was weighted by the number of fills. OOP: out-of-pocket cost. LIS: low-income subsidy.

Figure 6 shows out of pocket expense per fill for generic drugs by rurality.

Despite little evidence in difference in pharmacy use by rurality, our adjusted analysis estimated large differences in average OOP costs by pharmacy type. Mail order pharmacies had the lowest cost ($2.28) as compared to retail pharmacies ($3.57) and all other pharmacies ($6.18) (Figure 7).^§§§^

Figure 7 Adjusted OOP per Fill for Generic Drugs by Pharmacy Type

Note: Average OOP reflects average patient pay per 30-day equivalent. Restricted to generic formulations. Results from a linear regression with average OOP per 30-day equivalent as the outcome and controls for LIS indicator, plan type, pharmacy type, rurality, and interactions between LIS and each other variable. Regression included PEP fixed effects and was weighted by the number of fills. OOP: out-of-pocket cost. LIS: low-income subsidy. Missing pharmacy type is not presented.

Figure 7 shows the adjusted out of pocket expense for generic drugs by pharmacy type.

To assess how changes in pharmacy utilization might change OOP burden, we estimated the same regression as used for Figure 7 and generated an overall estimate of adjusted OOP^****^ as well as an estimate of average OOP if all prescriptions were filled at mail order pharmacies. We multiplied the difference between these two numbers by the total number of 30-day equivalents filled at mail order pharmacies, assuming that use of these pharmacies doubles. Our estimate indicated that this would lead to a reduction of $298.9 million in OOP costs, or roughly five percent of all OOP costs for generic drugs.

## CONCLUSION

There is wide variation in the use and average OOP cost of generic drugs by Medicare Part D enrollees. While a most enrollees face very low costs, particularly among the LIS population, other enrollees face higher costs. Over 12 percent of Part D enrollees faced copayments over $20 for a single fill of a generic drug. Even among some of the most commonly used generic drugs, fills for more than $2 were common, and accounted for nearly half of some prescriptions. Our results show that a variety of factors, including plan type, region (rural versus non-rural), and pharmacy type, can affect OOP cost.

As implementation of the Inflation Reduction Act continues, more enrollees will benefit through reduced cost-sharing and improved access to prescription drugs. Our findings indicate that there may be substantial, additional cost-sharing burdens that can be alleviated with a more standardized formulary targeted at high-value, generic prescription drugs. The M2DL model could help enrollees access lower cost drugs irrespective of these factors, reducing potential confusion among enrollees and improving adherence to high-value therapies. These improvements could lead to increased beneficiary adherence to chronic care medications, improved clinical outcomes, and lower overall costs for Medicare. Additionally, greater transparency in OOP costs would benefit physicians when prescribing.

Figure A1 Cost-Sharing Distributions for Generic Drugs by Plan Type, Non-LIS, 2022

Note: Percentages reflect the share of 30-day equivalents falling into each cost-sharing category. Restricted to generic formulations. EGWP: Employer Group Waiver Plans. MA-PD: Medicare Advantage Prescription Drug Plans. PDP: Standalone Prescription Drug Plans. LIS: low-income subsidy.

Figure A1 shows the cost sharing distributions for generic drugs by plan type for non-LIS in 2022.

Figure A2 Cost-Sharing Distributions for Generic Drugs by Rurality, Non-LIS, 2022

Note: Percentages reflect the share of 30-day equivalents falling into each cost-sharing category. Restricted to generic formulations. Excludes areas that could not be classified. LIS: low-income subsidy.

Figure A2 shows the cost sharing distributions for generic drugs by rurality for non-LIS in 2022.

Table A1 Out-of-Pocket Payments by Plan Type, Copay Level, and LIS Status, 2022

Copay Level | Plan Type | LIS Status | 30-Day Equivalents | Total OOP / GDC | Mean OOP per 30-Day Equivalent | Annual OOP | | Annual OOP / GDC
Copay Level | Plan Type | LIS Status | 30-Day Equivalents | Total OOP / GDC | Mean OOP per 30-Day Equivalent | Mean | Median | Mean | Median
<= $2 | All | All | 1,376,385,905 | 2.6% | $0.35 | $12.38 | $1.82 | 18.9% | 2.3%
<= $2 | All | LIS | 584,095,971 | 1.3% | $0.32 | $15.83 | $3.64 | 5.3% | 0.9%
<= $2 | All | Non-LIS | 792,289,934 | 6.1% | $0.37 | $10.90 | $1.65 | 24.8% | 5.2%
<= $2 | EGWP | All | 75,908,414 | 6.5% | $0.90 | $19.14 | $9.24 | 40.4% | 25.0%
<= $2 | EGWP | LIS | 4,972,070 | 1.1% | $0.32 | $14.79 | $0.00 | 4.7% | 0.0%
<= $2 | EGWP | Non-LIS | 70,936,344 | 7.4% | $0.94 | $19.28 | $9.47 | 41.5% | 25.0%
<= $2 | MAPD | All | 826,772,472 | 1.8% | $0.22 | $8.75 | $0.00 | 10.8% | 0.0%
<= $2 | MAPD | LIS | 364,977,484 | 1.3% | $0.24 | $12.50 | $0.00 | 4.6% | 0.0%
<= $2 | MAPD | Non-LIS | 461,794,989 | 3.2% | $0.20 | $6.77 | $0.00 | 14.2% | 0.0%
<= $2 | PDP | All | 473,705,018 | 3.0% | $0.49 | $15.86 | $5.94 | 24.8% | 9.1%
<= $2 | PDP | LIS | 214,146,418 | 1.4% | $0.44 | $21.20 | $10.03 | 6.5% | 2.5%
<= $2 | PDP | Non-LIS | 259,558,601 | 12.8% | $0.53 | $13.54 | $4.75 | 32.8% | 19.6%
> $2 | All | All | 574,959,660 | 36.8% | $9.08 | $182.82 | $90.91 | 60.2% | 61.0%
> $2 | All | LIS | 36,219,680 | 12.9% | $5.09 | $58.70 | $27.65 | 30.1% | 21.2%
> $2 | All | Non-LIS | 538,739,980 | 39.5% | $9.35 | $198.16 | $103.97 | 64.0% | 65.9%
> $2 | EGWP | All | 118,693,819 | 23.3% | $6.55 | $185.61 | $125.88 | 46.1% | 40.8%
> $2 | EGWP | LIS | 540,976 | 16.4% | $6.01 | $89.63 | $39.50 | 31.4% | 24.3%
> $2 | EGWP | Non-LIS | 118,152,843 | 23.4% | $6.55 | $186.45 | $126.78 | 46.2% | 41.0%
> $2 | MAPD | All | 201,550,446 | 38.6% | $9.75 | $148.11 | $70.00 | 60.2% | 61.0%
> $2 | MAPD | LIS | 22,269,066 | 13.6% | $5.08 | $53.99 | $25.79 | 29.9% | 21.4%
> $2 | MAPD | Non-LIS | 179,281,381 | 43.4% | $10.33 | $165.79 | $84.30 | 65.9% | 68.3%
> $2 | PDP | All | 254,715,394 | 43.0% | $9.73 | $223.22 | $106.54 | 65.7% | 69.5%
> $2 | PDP | LIS | 13,409,638 | 11.9% | $5.06 | $67.39 | $31.60 | 30.4% | 20.8%
> $2 | PDP | Non-LIS | 241,305,756 | 46.4% | $9.99 | $238.76 | $119.52 | 69.2% | 73.4%
> $2 & <= $5 | All | All | 316,152,309 | 29.0% | $3.95 | $54.39 | $35.04 | 60.7% | 60.7%
> $2 & <= $5 | All | LIS | 33,228,797 | 10.9% | $4.14 | $44.90 | $23.70 | 29.3% | 20.7%
> $2 & <= $5 | All | Non-LIS | 282,923,511 | 36.5% | $3.93 | $55.85 | $36.52 | 65.5% | 69.7%
> $2 & <= $5 | EGWP | All | 67,287,366 | 22.8% | $3.87 | $70.46 | $45.00 | 58.8% | 53.3%
> $2 & <= $5 | EGWP | LIS | 396,656 | 12.7% | $4.14 | $47.74 | $26.60 | 33.2% | 24.1%
> $2 & <= $5 | EGWP | Non-LIS | 66,890,710 | 22.9% | $3.87 | $70.68 | $45.00 | 59.1% | 53.8%
> $2 & <= $5 | MAPD | All | 103,143,194 | 25.7% | $3.86 | $41.00 | $23.45 | 56.7% | 52.3%
> $2 & <= $5 | MAPD | LIS | 20,412,658 | 11.6% | $4.14 | $41.41 | $22.75 | 28.9% | 20.7%
> $2 & <= $5 | MAPD | Non-LIS | 82,730,536 | 38.4% | $3.79 | $40.89 | $23.62 | 64.2% | 65.5%
> $2 & <= $5 | PDP | All | 145,721,748 | 36.4% | $4.06 | $61.75 | $45.39 | 65.4% | 71.3%
> $2 & <= $5 | PDP | LIS | 12,419,483 | 9.9% | $4.15 | $51.99 | $27.65 | 29.9% | 20.5%
> $2 & <= $5 | PDP | Non-LIS | 133,302,266 | 48.9% | $4.05 | $62.87 | $48.00 | 69.5% | 77.6%
> $5 & <= $10 | All | All | 163,463,635 | 40.4% | $8.24 | $86.37 | $51.05 | 68.4% | 74.9%
> $5 & <= $10 | All | LIS | 1,816,339 | 26.1% | $8.24 | $55.05 | $32.00 | 49.8% | 38.8%
> $5 & <= $10 | All | Non-LIS | 161,647,297 | 40.7% | $8.24 | $86.92 | $51.72 | 68.8% | 75.4%
> $5 & <= $10 | EGWP | All | 42,334,801 | 26.5% | $7.87 | $126.27 | $80.00 | 56.0% | 53.0%
> $5 & <= $10 | EGWP | LIS | 116,476 | 25.2% | $8.44 | $102.10 | $58.43 | 48.8% | 42.2%
> $5 & <= $10 | EGWP | Non-LIS | 42,218,325 | 26.5% | $7.87 | $126.36 | $80.00 | 56.0% | 53.1%
> $5 & <= $10 | MAPD | All | 60,008,871 | 45.1% | $8.40 | $69.00 | $39.27 | 70.4% | 77.8%
> $5 & <= $10 | MAPD | LIS | 1,142,733 | 25.4% | $8.18 | $49.11 | $29.00 | 49.4% | 37.0%
> $5 & <= $10 | MAPD | Non-LIS | 58,866,137 | 45.8% | $8.41 | $69.54 | $39.75 | 71.0% | 78.6%
> $5 & <= $10 | PDP | All | 61,119,964 | 53.3% | $8.33 | $90.20 | $57.29 | 71.7% | 82.2%
> $5 & <= $10 | PDP | LIS | 557,129 | 28.0% | $8.32 | $64.46 | $40.80 | 50.9% | 43.4%
> $5 & <= $10 | PDP | Non-LIS | 60,562,834 | 53.7% | $8.33 | $90.53 | $57.62 | 71.9% | 82.5%
> $10 & <= $20 | All | All | 63,637,240 | 48.2% | $15.18 | $104.71 | $53.58 | 70.9% | 80.5%
> $10 & <= $20 | All | LIS | 823,906 | 32.8% | $15.43 | $79.69 | $43.20 | 56.5% | 58.0%
> $10 & <= $20 | All | Non-LIS | 62,813,334 | 48.5% | $15.18 | $105.15 | $53.88 | 71.2% | 80.8%
> $10 & <= $20 | EGWP | All | 7,195,272 | 26.7% | $13.93 | $110.31 | $61.64 | 56.2% | 52.8%
> $10 & <= $20 | EGWP | LIS | 22,082 | 25.6% | $14.87 | $93.82 | $47.97 | 53.6% | 50.0%
> $10 & <= $20 | EGWP | Non-LIS | 7,173,190 | 26.7% | $13.93 | $110.38 | $61.64 | 56.2% | 52.9%
| MAPD | All | 25,391,991 | 50.3% | $15.19 | $84.06 | $43.11 | 73.2% | 83.0%
| MAPD | LIS | 490,981 | 30.5% | $15.27 | $67.11 | $38.28 | 56.7% | 57.8%
| MAPD | Non-LIS | 24,901,011 | 50.9% | $15.19 | $84.48 | $43.35 | 73.6% | 83.5%
| PDP | All | 31,049,976 | 55.7% | $15.46 | $128.76 | $66.23 | 71.6% | 83.4%
| PDP | LIS | 310,843 | 38.0% | $15.72 | $110.28 | $59.89 | 56.4% | 59.4%
| PDP | Non-LIS | 30,739,133 | 56.0% | $15.45 | $128.99 | $66.34 | 71.8% | 83.6%
> $20 | All | All | 31,706,476 | 36.5% | $52.30 | $255.99 | $126.62 | 71.1% | 79.4%
> $20 | All | LIS | 350,638 | 28.7% | $54.17 | $191.13 | $97.00 | 59.3% | 60.6%
> $20 | All | Non-LIS | 31,355,838 | 36.6% | $52.28 | $257.00 | $127.00 | 71.3% | 79.7%
> $20 | EGWP | All | 1,876,380 | 15.1% | $44.46 | $207.63 | $108.00 | 46.5% | 35.0%
> $20 | EGWP | LIS | 5,762 | 17.5% | $52.08 | $166.51 | $87.82 | 46.2% | 33.0%
> $20 | EGWP | Non-LIS | 1,870,618 | 15.1% | $44.44 | $207.81 | $108.16 | 46.5% | 35.0%
> $20 | MAPD | All | 13,006,390 | 40.7% | $52.01 | $217.55 | $100.00 | 77.1% | 95.7%
> $20 | MAPD | LIS | 222,693 | 29.3% | $53.08 | $171.78 | $90.00 | 62.1% | 69.9%
> $20 | MAPD | Non-LIS | 12,783,697 | 41.0% | $51.99 | $218.59 | $100.00 | 77.4% | 96.1%
> $20 | PDP | All | 16,823,706 | 38.7% | $53.39 | $302.83 | $158.40 | 68.2% | 69.8%
> $20 | PDP | LIS | 122,183 | 28.4% | $56.24 | $238.99 | $131.33 | 53.3% | 50.0%
> $20 | PDP | Non-LIS | 16,701,523 | 38.8% | $53.37 | $303.45 | $158.86 | 68.4% | 70.0%

Note: Restricted to generic formulations only. EGWP: Employer Group Waiver Plans. MA-PD: Medicare Advantage Prescription Drug Plans. PDP: Standalone Prescription Drug Plans. LIS: low-income subsidy. OOP: out-of-pocket cost. GDC: gross drug costs.

Table A2 Top 20 Drugs by Volume, LIS, 2022

Active Ingredient | % 30-Day Equivalent <= $2 | Average OOP
Atorvastatin Calcium | 98.3% | $0.29
Amlodipine Besylate | 98.5% | $0.28
Metformin HCl | 98.5% | $0.27
Lisinopril | 98.4% | $0.28
Gabapentin | 89.4% | $0.78
Omeprazole | 96.6% | $0.47
Losartan Potassium | 98.2% | $0.30
Furosemide | 97.6% | $0.31
Metoprolol Succinate | 96.5% | $0.49
Pantoprazole Sodium | 96.2% | $0.45
Levothyroxine Sodium | 97.1% | $0.40
Rosuvastatin Calcium | 97.9% | $0.36
Trazodone HCl | 95.2% | $0.46
Metoprolol Tartrate | 97.8% | $0.31
Carvedilol | 97.2% | $0.37
Hydrochlorothiazide | 98.6% | $0.27
Tamsulosin HCl | 96.2% | $0.48
Simvastatin | 98.7% | $0.27
Sertraline HCl | 96.5% | $0.37
Montelukast Sodium | 96.9% | $0.40

Note: Restricted to generic formulations. LIS: low-income subsidy. OOP: out-of-pocket costs.

Table A3 Top 100 Drugs by Volume and Indications, 2022

Active Ingredient | Examples of Condition(s) Treated
Albuterol Sulfate | Asthma, chronic obstructive pulmonary disease
Alendronate Sodium | Osteoporosis
Allopurinol | Gout and kidney stones.
Alprazolam | Anxiety disorder, panic disorder
Amiodarone HCl | Irregular heartbeat
Amitriptyline HCl | Depression
Amlodipine Besylate | Hypertension
Atenolol | Hypertension
Atorvastatin Calcium | Hypercholesterolemia
Baclofen | Pain due to multiple sclerosis, spinal cord injury
Benazepril HCl | Hypertension
Bupropion HCl | Depression, smoking cessation, seasonal affective disorder
Buspirone HCl | Generalized anxiety disorder
Carbidopa-Levodopa | Parkinson's disease
Carvedilol | Heart failure, hypertension
Celecoxib | Pain, arthritis
Chlorthalidone | Hypertension, edema
Citalopram Hydrobromide | Depression
Clonazepam | Panic disorder, epilepsy
Clonidine HCl | Hypertension
Clopidogrel Bisulfate | Coronary artery disease, stoke prevention
Cyclobenzaprine HCl | Muscle spasms
Diltiazem HCl Coated Beads | High blood pressure, angina
Divalproex Sodium | Seizures
Donepezil Hydrochloride | Alzheimer's Disease
Dorzolamide HCl-Timolol Maleate | Glaucoma
Doxazosin Mesylate | Benign prostatic hyperplasia, hypertension
Duloxetine HCl | Depression, anxiety, nerve pain
Enalapril Maleate | Hypertension
Escitalopram Oxalate | Depression, anxiety
Esomeprazole Magnesium | Ulcers, erosive esophagitis, gastroesophageal reflux disease
Ezetimibe | Hypercholesterolemia
Famotidine | Ulcers, gastroesophageal reflux disease
Fenofibrate | Hypercholesterolemia, high triglycerides
Finasteride | Benign prostate hyperplasia, androgenic alopecia
Fluoxetine HCl | Depression, panic attacks, obsessive compulsive disorder
Fluticasone Propionate (Nasal) | Nonallergic rhinitis
Furosemide | Heart failure, edema
Gabapentin | Seizures, nerve pain
Glimepiride | Diabetes
Glipizide | Diabetes
Hydralazine HCl | Hypertension
Hydrochlorothiazide | Hypertension, edema
Hydrocodone-Acetaminophen | Pain
Hydroxychloroquine Sulfate | Malaria, rheumatoid arthritis
Ibuprofen | Pain
Irbesartan | Hypertension
Isosorbide Mononitrate | Chest pain, heart failure
Lamotrigine | Seizures, bipolar disorder
Latanoprost | Glaucoma
Levetiracetam | Seizures
Levothyroxine Sodium | Hypothyroidism
Lisinopril | Hypertension, heart failure
Lisinopril & Hydrochlorothiazide | Hypertension
Lorazepam | Seizure disorders
Losartan Potassium | Hypertension
Losartan Potassium & Hydrochlorothiazide | Hypertension
Lovastatin | Hypercholesterolemia
Meloxicam | Pain, arthritis
Memantine HCl | Dementia, Alzheimer's Disease
Metformin HCl | Diabetes
Metoprolol Succinate | Hypertension, angina, heart failure
Metoprolol Tartrate | Hypertension, Angina, Heart Failure
Mirtazapine | Major depressive disorder
Montelukast Sodium | Asthma
Nifedipine | Hypertension, angina
Olmesartan Medoxomil | Hypertension
Omeprazole | Gastroesophageal reflux disease
Oxybutynin Chloride | Urinary urgency
Oxycodone HCl | Pain
Oxycodone w/ Acetaminophen | Pain
Pantoprazole Sodium | Gastroesophageal reflux disease
Paroxetine HCl | Depression, panic attacks, obsessive compulsive disorder, anxiety disorders
Pioglitazone HCl | Diabetes
Potassium Chloride | Potassium supplementation
Potassium Chloride Microencapsulated Crystals | Potassium supplementation
Pravastatin Sodium | Hypercholesterolemia
Prednisone | Anti-inflammatory steroid
Pregabalin | Seizures, nerve pain, fibromyalgia
Propranolol HCl | Tremors, angina, hypertension, heart rhythm disorders
Quetiapine Fumarate | Schizophrenia, bipolar disorder, and depression
Ropinirole Hydrochloride | Parkinson's disease
Rosuvastatin Calcium | Hypercholesterolemia
Sertraline HCl | Depression, obsessive-compulsive disorder, posttraumatic stress disorder
Simvastatin | Hypercholesterolemia
Spironolactone | Hypertension, edema
Tamsulosin HCl | Benign prostatic hyperplasia
Timolol Maleate (Ophthalmic) | Glaucoma
Tizanidine HCl | Muscle spasms due to multiple sclerosis
Topiramate | Epilepsy, migraines
Torsemide | Edema
Tramadol HCl | Pain
Trazodone HCl | Depression and insomnia
Triamcinolone Acetonide (Topical) | Eczema, dermatitis, allergies, rash
Triamterene & Hydrochlorothiazide | Hypertension, edema
Valsartan | Hypertension, heart failure
Venlafaxine HCl | Major depressive disorder, anxiety, and panic disorder
Warfarin Sodium | Blood clots
Zolpidem Tartrate | Insomnia

Note: Restricted to generic formulations.

Table A4 Top 20 Drugs by Volume, Non-LIS, EGWP, 2022

Active Ingredient | Generic 30-Day Equivalents | Mean Generic OOP | % Fills >$2
Atorvastatin Calcium | 11,486,921 | $3.10 | 55.8%
Amlodipine Besylate | 7,542,593 | $2.07 | 36.5%
Metoprolol Succinate | 6,430,247 | $4.15 | 67.5%
Metformin HCL | 6,010,616 | $2.60 | 47.5%
Losartan Potassium | 5,766,899 | $3.40 | 62.2%
Lisinopril | 5,299,405 | $2.15 | 39.2%
Rosuvastatin Calcium | 5,282,480 | $3.68 | 60.2%
Omeprazole | 4,210,408 | $3.86 | 65.8%
Furosemide | 3,957,820 | $2.02 | 38.1%
Pantoprazole Sodium | 3,684,181 | $4.07 | 70.8%
Gabapentin | 3,672,579 | $4.30 | 67.6%
Levothyroxine Sodium | 3,619,449 | $4.20 | 73.6%
Tamsulosin HCl | 3,549,538 | $4.12 | 68.0%
Hydrochlorothiazide | 3,179,135 | $1.55 | 26.1%
Simvastatin | 3,084,964 | $2.23 | 41.2%
Metoprolol Tartrate | 2,785,463 | $2.30 | 42.6%
Carvedilol | 2,714,159 | $2.98 | 56.7%
Montelukast Sodium | 2,540,505 | $3.91 | 65.0%
Clopidogrel Bisulfate | 2,267,828 | $3.85 | 64.1%
Allopurinol | 2,014,321 | $3.28 | 60.4%

Note: Restricted to generic formulations and non-LIS enrollees. LIS: low-income subsidy. OOP: out-of-pocket costs. EGWP: Employer Group Waiver Plans.

Table A5 Top 20 Drugs by Volume, Non-LIS, MA-PD, 2022

Active Ingredient | Generic 30-Day Equivalents | Mean Generic OOP | % Fills >$2
Atorvastatin Calcium | 48,376,551 | $0.67 | 12.0%
Amlodipine Besylate | 32,583,496 | $0.55 | 8.3%
Lisinopril | 28,051,724 | $0.46 | 7.1%
Metformin HCl | 24,580,456 | $0.49 | 7.9%
Losartan Potassium | 23,919,251 | $0.61 | 11.4%
Metoprolol Succinate | 18,582,829 | $1.69 | 27.2%
Rosuvastatin Calcium | 16,991,014 | $0.77 | 12.9%
Omeprazole | 16,694,235 | $1.96 | 31.6%
Levothyroxine Sodium | 14,799,723 | $1.52 | 26.0%
Simvastatin | 14,466,847 | $0.43 | 6.3%
Hydrochlorothiazide | 14,273,918 | $0.45 | 6.8%
Gabapentin | 13,189,292 | $4.21 | 50.4%
Tamsulosin HCl | 12,734,673 | $1.84 | 32.5%
Pantoprazole Sodium | 11,802,997 | $1.26 | 23.3%
Metoprolol Tartrate | 10,950,423 | $0.66 | 12.0%
Furosemide | 10,852,750 | $0.65 | 11.1%
Carvedilol | 9,299,698 | $0.80 | 15.8%
Clopidogrel Bisulfate | 8,153,639 | $2.25 | 32.8%
Pravastatin Sodium | 7,920,209 | $0.87 | 14.9%
Sertraline HCl | 7,066,957 | $1.13 | 21.8%

Note: Restricted to generic formulations and non-LIS enrollees. LIS: low-income subsidy. OOP: out-of-pocket costs. MA-PD: Medicare Advantage Prescription Drug Plans.

Table A6 Top 20 Drugs by Volume, Non-LIS, PDP, 2022

Active Ingredient | Generic 30-Day Equivalents | Mean Generic OOP | % Fills >$2
Atorvastatin Calcium | 37,604,534 | $1.61 | 23.7%
Amlodipine Besylate | 25,501,144 | $1.37 | 20.6%
Lisinopril | 20,098,277 | $1.36 | 21.2%
Losartan Potassium | 19,391,472 | $1.91 | 30.5%
Metoprolol Succinate | 17,565,519 | $4.15 | 68.6%
Metformin HCl | 16,392,432 | $1.35 | 19.4%
Rosuvastatin Calcium | 13,930,481 | $4.72 | 63.6%
Omeprazole | 13,685,083 | $3.03 | 44.1%
Levothyroxine Sodium | 12,920,319 | $2.90 | 37.1%
Hydrochlorothiazide | 11,826,351 | $0.87 | 11.3%
Simvastatin | 10,937,144 | $1.41 | 20.9%
Pantoprazole Sodium | 10,356,833 | $4.37 | 67.2%
Tamsulosin HCl | 9,831,473 | $4.79 | 75.7%
Furosemide | 9,530,245 | $1.39 | 23.5%
Gabapentin | 9,498,331 | $5.37 | 71.3%
Metoprolol Tartrate | 8,759,321 | $1.43 | 22.0%
Carvedilol | 7,646,329 | $2.28 | 35.4%
Clopidogrel Bisulfate | 6,678,742 | $3.40 | 52.7%
Pravastatin Sodium | 6,532,924 | $3.05 | 47.7%
Sertraline HCl | 5,988,497 | $2.12 | 30.4%

Note: Restricted to generic formulations and non-LIS enrollees. LIS: low-income subsidy. OOP: out-of-pocket costs. PDP: Standalone Prescription Drug plans.

Table A7 Representation and OOP for the 20 Most Utilized Generic Drugs by Race & Ethnicity, Overall, 2022

Drug | Overall | | White | | Asian | | Black | | Hispanic | | American Indian/Alaska Native | | Other
Drug | Rank | Average OOP | Rank | Average OOP | Rank | Average OOP | Rank | Average OOP | Rank | Rank | Rank | Average OOP | Rank | Average OOP
Atorvastatin Calcium | 1 | $0.97 | 1 | $1.20 | 1 | $0.58 | 2 | $0.71 | 1 | $0.46 | 1 | $1.26 | 1 | $0.96
Amlodipine Besylate | 2 | $1.20 | 2 | $0.98 | 2 | $0.47 | 1 | $0.58 | 3 | $0.42 | 4 | $1.08 | 2 | $0.74
Lisinopril | 3 | $1.28 | 3 | $0.87 | 6 | $0.48 | 5 | $0.51 | 4 | $0.37 | 2 | $0.98 | 4 | $0.74
Metformin HCl | 4 | $1.23 | 5 | $0.96 | 3 | $0.53 | 3 | $0.58 | 2 | $0.41 | 3 | $1.36 | 3 | $0.80
Losartan Potassium | 5 | $0.86 | 4 | $1.38 | 4 | $0.60 | 4 | $0.80 | 5 | $0.49 | 6 | $1.69 | 5 | $1.04
Metoprolol Succinate | 6 | $0.41 | 6 | $2.76 | 5 | $1.39 | 8 | $1.52 | 8 | $1.04 | 9 | $2.13 | 6 | $2.40
Omeprazole | 7 | $0.53 | 7 | $2.12 | 10 | $1.10 | 11 | $1.26 | 6 | $0.95 | 7 | $2.41 | 8 | $1.75
Rosuvastatin Calcium | 8 | $0.46 | 8 | $2.52 | 7 | $1.21 | 13 | $1.16 | 9 | $0.78 | 11 | $3.67 | 7 | $2.29
Gabapentin | 9 | $0.33 | 10 | $3.57 | 13 | $1.66 | 7 | $1.90 | 7 | $1.31 | 5 | $2.63 | 13 | $2.88
Levothyroxine Sodium | 10 | $0.53 | 9 | $2.04 | 11 | $1.42 | 24 | $1.18 | 10 | $0.98 | 19 | $1.48 | 12 | $1.82
Pantoprazole Sodium | 11 | $0.48 | 11 | $2.38 | 14 | $1.26 | 12 | $1.13 | 12 | $0.90 | 10 | $2.31 | 14 | $2.06
Hydrochlorothiazide | 12 | $1.59 | 13 | $0.71 | 16 | $0.45 | 6 | $0.45 | 13 | $0.32 | 13 | $0.93 | 10 | $0.58
Furosemide | 13 | $1.16 | 12 | $0.96 | 22 | $0.54 | 9 | $0.58 | 15 | $0.42 | 8 | $1.03 | 17 | $0.77
Simvastatin | 14 | $1.19 | 14 | $0.96 | 9 | $0.45 | 16 | $0.59 | 11 | $0.34 | 12 | $1.49 | 11 | $0.76
Tamsulosin HCl | 15 | $0.39 | 15 | $2.94 | 8 | $1.46 | 15 | $1.69 | 14 | $1.23 | 15 | $1.88 | 9 | $2.68
Metoprolol Tartrate | 16 | $1.09 | 16 | $1.02 | 18 | $0.53 | 14 | $0.62 | 18 | $0.44 | 20 | $1.07 | 15 | $0.80
Carvedilol | 17 | $0.79 | 17 | $1.47 | 17 | $0.75 | 10 | $0.84 | 16 | $0.59 | 14 | $1.65 | 16 | $1.19
Clopidogrel Bisulfate | 18 | $0.46 | 20 | $2.44 | 19 | $1.34 | 17 | $1.41 | 21 | $1.08 | 21 | $2.56 | 19 | $2.06
Trazodone HCl | 19 | $0.66 | 19 | $1.70 | 32 | $0.86 | 27 | $0.78 | 23 | $0.66 | 17 | $1.40 | 23 | $1.54
Sertraline HCl | 20 | $0.77 | 18 | $1.43 | 36 | $0.88 | 37 | $0.72 | 24 | $0.59 | 22 | $0.99 | 22 | $1.16

Note: Restricted to generic formulation. Includes LIS and non-LIS. LIS: low-income subsidy. OOP: out-of-pocket cost.

## REFERENCES

1 The Hatch-Waxman Act: A Primer. 2016. Sept 28. https://www.everycrsreport.com/files/20160928_R44643_1c2fafad2efe96d4c0fe44f2f23308dcfc059f83.pdf
2 Dickson SR, Kent T. Association of Generic Competition With Price Decreases in Physician-Administered Drugs and Estimated Price Decreases for Biosimilar Competition. JAMA Netw Open. Nov 1 2021;4(11):e2133451. doi:10.1001/jamanetworkopen.2021.33451 34779844
3 Nguyen NX, Sheingold SH, Tarazi W, Bosworth A. Effect of Competition on Generic Drug Prices. Appl Health Econ Health Policy. Mar 2022;20(2):243–253. doi:10.1007/s40258-021-00705-w 34904207
4 Nguyen NX, Sheingold SH, Tarazi W, Bosworth A. Medicare Part D: Competition and Generic Drug Prices, 2007–2018. 2021. Jan 19.
5 Sheingold S, Nguyen NX. Impacts of generic competition and benefit management practices on spending for prescription drugs: evidence from Medicare's Part D benefit. Medicare Medicaid Res Rev. 2014;4(1)doi:10.5600/mmrr.004.01.a01
6 Conrad RL, R. Generic Competition and Drug Prices: New Evidence Linking Greater Generic Competition and Lower Generic Drug Prices. 2019. December. https://www.fda.gov/media/133509/download
7 Parasrampuria S, Murphy S. Trends in Prescription Drug Spending, 2016–2021. 2022. https://aspe.hhs.gov/sites/default/files/documents/88c547c976e915fc31fe2c6903ac0bc9/sdp-trends-prescription-drug-spending.pdf
8 Buttorff C, Xu Y, Joyce G. Variation in generic dispensing rates in Medicare Part D. Am J Manag Care. Nov 1 2020;26(11):e355–e361. doi:10.37765/ajmc.2020.88530 33196286
9 Joyce G, Henkhaus LE, Gascue L, Zissimopoulos J. Generic Drug Price Hikes And Out-Of-Pocket Spending For Medicare Beneficiaries. Health Aff (Millwood). Oct 2018;37(10):1578–1586. doi:10.1377/hlthaff.2018.0628 30273018
10 Frank RG, Hicks A, Berndt ER. The Price to Consumers of Generic Pharmaceuticals: Beyond the Headlines. Med Care Res Rev. Oct 2021 2021;78(5):585–590. doi:10.1177/1077558720921100 32468959
11 Hernandez I, Gabriel N, Kaltenboeck A, Boccuti C, Hansen RN, Sullivan SD. Reimbursement to Pharmacies for Generic Drugs by Medicare Part D Sponsors. JAMA. Dec 5 2023;doi:10.1001/jama.2023.21481
12 8 Reasons Patients Don’t Take Their Medications. American Medical Association. https://www.ama-assn.org/delivering-care/patient-support-advocacy/8-reasons-patients-dont-take-their-medications
13 Kirzinger A, Montero A, Sparks G, Valdes I, Hamel L. Public Opinion on Prescription Drugs and Their Prices. KFF. https://www.kff.org/health-costs/poll-finding/public-opinion-on-prescription-drugs-and-their-prices/
14 Nekui F, Galbraith AA, Briesacher BA, Cost-related Medication Nonadherence and Its Risk Factors Among Medicare Beneficiaries. Med Care. Jan 2021 2021;59(1):13–21. doi:10.1097/MLR.0000000000001458 33298705
15 Socal MP, Bai G, Anderson GF. Favorable Formulary Placement of Branded Drugs in Medicare Prescription Drug Plans When Generics Are Available. JAMA Intern Med. Jun 1 2019;179(6):832–833. doi:10.1001/jamainternmed.2018.7824 30882842
16 Hsu J, Fung V, Price M, Medicare beneficiaries' knowledge of Part D prescription drug program benefits and responses to drug costs. JAMA. Apr 23 2008;299(16):1929–36. doi:10.1001/jama.299.16.1929 18430912
17 Pham HH, Alexander GC, O'Malley AS. Physician consideration of patients' out-of-pocket costs in making common clinical decisions. Arch Intern Med. Apr 9 2007;167(7):663–8. doi:10.1001/archinte.167.7.663 17420424
18 Eaddy MT, Cook CL, O'Day K, Burch SP, Cantrell CR. How patient cost-sharing trends affect adherence and outcomes: a literature review. P T. Jan 2012;37(1):45–55.22346336
19 Briesacher BA, Andrade SE, Fouayzi H, Chan KA. Medication adherence and use of generic drug therapies. Am J Manag Care. Jul 2009;15(7):450–6.19589012
20 Schikowski EM, Swabe G, Chan SY, Magnani JW. Association Between Copayment and Adherence to Medications for Pulmonary Arterial Hypertension. J Am Heart Assoc. Nov 15 2022;11(22):e026620. doi:10.1161/JAHA.122.026620 36370005
21 Pawaskar MD, Xu L, Tang Y, Puckrein GA, Rajpathak SN, Stuart B. Effect of Medication Copayment on Adherence and Discontinuation in Medicare Beneficiaries with Type 2 Diabetes: A Retrospective Administrative Claims Database Analysis. Diabetes Ther. Oct 2018;9(5):1979–1993. doi:10.1007/s13300-018-0489-y 30143964
22 Choudhry NK, Fischer MA, Avorn J, At Pitney Bowes, value-based insurance design cut copayments and increased drug adherence. Health Aff (Millwood). Nov 2010;29(11):1995–2001. doi:10.1377/hlthaff.2010.0336 21041738
23 Chernew ME, Shah MR, Wegh A, Impact of decreasing copayments on medication adherence within a disease management environment. Health Aff(Millwood). Jan-Feb 2008;27(1):103–12. doi:10.1377/hlthaff.27.1.103 18180484
24 Jimenez M, Alvarez G, Wertheimer A, The Effect of Zero Copayments on Medication Adherence in a Community Pharmacy Setting. Innov Pharm. 2019;10(2)doi:10.24926/iip.v10i2.1633
25 Chandra A, Gruber J, McKnight R. Patient Cost-Sharing and Hospitalization Offsets in the Elderly. Am Econ Rev. Mar 1 2010;100(1):193–213. doi:10.1257/aer.100.1.193 21103385
26 Chandra A, Flack E, Obermeyer Z. The Health Costs of Cost-Sharing. National Bureau of Economic Research. February 2021;
27 Choudhry NK, Avorn J, Glynn RJ, Full coverage for preventive medications after myocardial infarction. N Engl J Med. Dec 1 2011;365(22):2088–97. doi:10.1056/NEJMsa1107913 22080794
28 Executive Order 14087—Lowering Prescription Drug Costs for Americans (2022). https://www.govinfo.gov/content/pkg/FR-2022-10-19/pdf/2022-22834.pdf
29 Becerra X. A Report in Response to the Executive Order on Lowering Prescription Drug Costs for Americans. 2023. Feb 14. https://www.cms.gov/priorities/innovation/data-and-reports/2023/eo-rx-drug-cost-response-report
30 Fowler LM, L. CMS Innovation Center’s One-Year Update on the Executive Order to Lower Prescription Drug Costs for Americans. CMS Blog blog. October 11, 2023. https://www.cms.gov/blog/cms-innovation-centers-one-year-update-executive-order-lower-prescription-drug-costs-americans
31 Karaca-Mandic P, Swenson T, Abraham JM, Kane RL. Association of Medicare Part D medication out-of-pocket costs with utilization of statin medications. Health Serv Res. Aug 2013;48(4):1311–33. doi:10.1111/1475-6773.12022 23278369
32 Roberts ET, Glynn A, Cornelio N, Donohue JM, Gellad WF, McWilliams JM, Sabik LM. Medicaid Coverage 'Cliff' Increases Expenses And Decreases Care For Near-Poor Medicare Beneficiaries. Health Aff(Millwood). Apr 2021;40(4):552–561. doi:10.1377/hlthaff.2020.02272 33819086
33 Office of Management and Budget. 2020 Standards for Delineating Core Based Statistical Areas. In: Budget OoMa, editor. 86 FR 37770. Federal Register: Federal Register; 2021. p. 9.
34 Medicare Payment Advisory Commission. MedPAC 2023 Report to Congress: The Medicare prescription drug program (Part D): Status Report. 2023. March. https://www.medpac.gov/wp-content/uploads/2023/03/Ch12_Mar23_MedPAC_Report_To_Congress_SEC.pdf
35 Social Security Administration. Extra Help And Deemed Subsidy Eligible. https://secure.ssa.gov/poms.nsf/lnx/0603001005
36 Starc AT, Robert J. Externalities and Benefit Design in Health Insurance. The Review of Economic Studies. November 2019;87(6):31.
37 Dusetzina SB, Cubanski J, Roberts AW, Hoadley J, True S, Nshuti L, Neuman T. Trends in Medicare Part D coverage of generics with equivalent brand-name drugs. Am J Manag Care. Jul 2021 2021;27(7):283–288. doi:10.37765/ajmc.2021.88701 34314117
38 Onyinye Oyeka FU, Keith J. Mueller. Medicare Beneficiary Access to Prescription Drugs in Rural Areas. 2022. August. https://rupri.public-health.uiowa.edu/publications/policybriefs/2022/Access%20to%20Prescription%20Drugs.pdf
39 Fung V, Price M, Cheng D, Associations Between Annual Medicare Part D Low-Income Subsidy Loss and Prescription Drug Spending and Use. JAMA Health Forum. Feb 2 2024;5(2):e235152. doi:10.1001/jamahealthforum.2023.5152 38306091
40 Wei, II, Lloyd JT, Shrank WH. The relationship between the low-income subsidy and cost-related nonadherence to drug therapies in Medicare Part D. J Am Geriatr Soc. Aug 2013;61(8):1315–23. doi:10.1111/jgs.12364 23889465
41 Yala SM, Duru OK, Ettner SL, Turk N, Mangione CM, Brown AF. Patterns of prescription drug expenditures and medication adherence among medicare part D beneficiaries with and without the low-income supplement. BMC Health Serv Res. Dec 20 2014;14:665. doi:10.1186/s12913-014-0665-3 25526892
42 Chou YT, Farley JF, Stinchcombe TE, Proctor AE, Lafata JE, Dusetzina SB. The Association Between Medicare Low-Income Subsidy and Anticancer Treatment Uptake in Advanced Lung Cancer. J Natl Cancer Inst. Jun 1 2020;112(6):637–646. doi:10.1093/jnci/djz183 31501872
43 Centers for Medicare and Medicaid Services. 30 CCW Chronic Conditions Period Prevalence, 2021. 2023. April. https://www2.ccwdata.org/web/guest/medicare-charts/medicare-chronic-condition-charts
44 Jimenez DE, Park M, Rosen D, Centering Culture in Mental Health: Differences in Diagnosis, Treatment, and Access to Care Among Older People of Color. Am J Geriatr Psychiatry. Nov 2022;30(11):1234–1251. doi:10.1016/j.jagp.2022.07.001 35914985

* While generic utilization may benefit enrollees more generally through reduced premiums, this is a less direct effect for patients who take the drug.

† Recent efforts to make drug costs more transparent to enrollees include real-time benefit tools that PDP sponsors are required to offer as of 2023.

‡ Note that M2DL model parameters are still being determined, and changes to cost-sharing for certain drugs may signal other changes to achieve actuarial equivalence requirements. We do not explicitly consider these secondary effects.

§ For eligible enrollees whose income and resources are limited, the Medicare Prescription Drug, Improvement and Modernization Act of 2003 established the Low-Income Subsidy, also known as Extra Help. Subsidies are paid by the Federal government to drug plans and provide assistance with premiums, deductibles, and co-payments. Under the Inflation Reduction Act, beginning in 2024, the LIS program is expanded to individuals with limited financial resources and incomes up to 150 percent of the Federal Poverty Limit (FPL), which is about $21,870 per individual in 2023. For more information, please see here (https://www.cms.gov/training-education/partner-outreach-resources/low-income-subsidy-lis#:%7E:text=What%27s%20the%20Low%20Income%20Subsidy,of%20Medicare%20prescription%20drug%20coverage.).

** ANDAs are the applications submitted to FDA for review and potential approval of a generic drug.

†† Note that this differs from the 30-day equivalent supply methodology used for the Medicare Drug Price Negotiation Program under the Inflation Reduction Act, which matches the methodology specified in 42 C.F.R. § 423.104(d)(2)(iv)(A)(2): if the days' supply reported on a PDE is less than or equal to 34, the number of 30-day equivalent supplies equals one. If the days' supply reported on a PDE is greater than 34, the number of 30-day equivalent supplies is equal to the number of days' supply reported on each PDE divided by 30.

‡‡ Among all Part D enrollees, there were 2,212 unique drugs with generic alternatives available and 887 unique active ingredients among all Part D enrollees.

§§ The gross drug cost represents total spending for the prescription claim, including Medicare, plan, and enrollee payments

*** EGWP plans are non-bidding plans, are not open to general enrollment, and have enrollment that is substantially different from other plans offered. These differences, in addition to differences in plan design, may contribute to differences in the likelihood of using generic drugs.

††† See: https://www.cms.gov/priorities/health-equity/rural-health

‡‡‡ Including brand-name drugs, the top 20 drugs accounted for 1.04 billion 30-day equivalents.

§§§ “All other pharmacies” includes institutional, long-term care, managed care organization, specialty, and any other pharmacies not categorized as mail order or retail. The vast majority of prescriptions are filled at retail pharmacies.

**** Stata’s -margins- command was used to generate these predicted values.