# Health Coverage Under the Affordable Care Act: Current Enrollment Trends and State Estimates

Issue Brief

This Issue Brief presents current estimates of enrollment in health insurance coverage obtained through the ACA Marketplaces and the Medicaid expansion and the subsequent reductions in state-level uninsured rates since the ACA was implemented in 2014. Based on 2023 and early 2024 enrollment data, more than 45 million people are currently enrolled in Marketplace or Medicaid expansion coverage under provisions of the Affordable Care Act (ACA), the highest total on record.

Based on 2023 and early 2024 enrollment data 45 million people are currently enrolled in Marketplace or Medicaid expansion coverage under provisions of the Affordable Care Act (ACA), the highest total on record.

## KEY POINTS

- Marketplaces and Medicaid expansion, programs created by the Affordable Care Act (ACA), have enrolled millions of Americans in participating states since their implementation in 2014.
- According to the most recently available administrative data, we estimate that about 20.5 million^*^ consumers were enrolled in Marketplace plans as of February 2024 (across all 50 states and the District of Columbia), and 18.6 million people (across 39 participating states^†^ and the District of Columbia) were newly enrolled in Medicaid as of September 2023 via the ACA’s expansion of eligibility to adults.
- In addition, 1.3 million individuals were enrolled in the ACA’s Basic Health Program option in February 2024, and 4.6 million non-newly eligible adults who were eligible under previous criteria gained coverage under the Medicaid ACA expansion.
- Across these coverage groups, a total of 45 million Americans were enrolled in coverage related to the ACA, the highest total on record. This represents 14.1 million more people enrolled than in 2021 (a 46% increase) and 32.5 million more people enrolled than in 2014 (a 258% increase, or more than triple).
- Marketplace enrollment continues to increase, reaching over 20 million for the 2024 plan year—a record high since the launch of the ACA Marketplaces a decade earlier.
- This trend has occurred in the context of an overall increase in health insurance coverage in recent years, including a decline in the uninsured rate—from 16 percent in 2010, prior to ACA implementation, to 7.7 percent in late 2023 according to the most recent federal survey data.

## BACKGROUND

The Affordable Care Act^1^ (ACA), which was signed into law in 2010, brought the largest expansion of coverage in the U.S. health care system since the creation of Medicare and Medicaid in 1965. A comprehensive health care reform law, the ACA expanded health insurance coverage to millions of Americans through two main pathways:

- Providing premium tax credits to consumers with incomes between 100% and 400% of the federal poverty level (FPL) to lower the cost of individual market health insurance purchased through new state Marketplaces;^‡^ and
- Expanding Medicaid eligibility to adults with incomes up to 138% Federal Poverty Level (FPL), in states that elect to cover these low-income adults.^§^

The ACA also provided states the option to implement a Basic Health Program (BHP) to cover low-income residents who would otherwise be eligible to purchase coverage through the health insurance Marketplaces.

Since implementation of the ACA in 2014, the number of uninsured Americans has fallen significantly. Between 2013 and 2022 the number of people without health insurance dropped by 42 percent, falling from 45.2 million to 26.4 million.^2,3^ In recent years, a number of federal policies aimed to support health insurance coverage have contributed to a steady decline in the uninsured population since 2020.^4^ These federal policies include:

- The Families First Coronavirus Response Act (FFCRA) provided states with additional federal financial support if they met certain conditions including agreeing to maintain the enrollment of most Medicaid beneficiaries during a period that began in March 2020 and ended on March 31, 2023.
- CMS has taken extensive regulatory and sub-regulatory actions to implement ACA provisions reducing coverage loss at Medicaid redetermination, including actions under the Consolidated Appropriations Act, 2023.
- The American Rescue Plan Act (ARP) of 2021 and the Inflation Reduction Act (IRA) of 2022 increased Marketplace premium tax credits for individuals and families with household incomes between 100 and 400 percent of the Federal Poverty Level (FPL) and extended eligibility for Marketplace premium tax credits to those with household income above 400 percent of the FPL.
- Administrative actions extending and establishing special enrollment periods for Marketplace coverage.

In addition, at the state level, seven states have implemented the ACA Medicaid expansions extending coverage to low-income adults with incomes up to 138% FPL since 2020 (Utah, Idaho, Nebraska, Oklahoma, Missouri, South Dakota, and North Carolina). These combined federal and state policies, along with a strong labor market, have contributed to increased insurance coverage.

During the 2024 Marketplace Open Enrollment Period, over 21.4 million people selected an ACA Health Insurance Marketplace plan. Total plan selections include more than five million people — about a fourth — who are new to the Marketplaces and 16 million people who renewed their coverage.^5^ Under the enhanced premium tax credits established under the American Rescue Plan and continued under the Inflation Reduction Act, four in five HealthCare.gov customers were able to find health care coverage for $10 or less per month for plan year 2024 after subsidies.^6^

This Issue Brief presents current estimates of enrollment in health insurance coverage obtained through the ACA Marketplaces and the Medicaid expansion and the subsequent reductions in state-level uninsured rates since the ACA was implemented in 2014. This issue brief updates our estimates released in March of 2023 where we found that about 40 million people gained coverage under the ACA.^7^

## METHODS

For both Marketplace and Medicaid expansion enrollment, we present the most recent administrative data with state-by-state totals from the Centers for Medicare & Medicaid Services (CMS), as well as historical national totals for the years 2014-2024.

There are two related measures of Marketplace enrollment. The first is plan selections, and the second is effectuated enrollment. At the end of each annual open enrollment period, CMS releases plan selections, which are the number of people who have selected a plan; CMS follows later with data on effectuated enrollment, which captures the number of people who have paid their first month’s premium (if applicable). In this report, Marketplace enrollment estimates reflect effectuated enrollment counts from both States with Marketplaces using the HealthCare.gov platform and those with State-based Marketplaces. Effectuated enrollment for 2024 is not yet available but was estimated from state February 2023 effectuation rates applied to the number of people selecting Marketplace plans during the 2024 Open Enrollment Period. This brief uses effectuated enrollment so that our overall coverage estimates can be compared over time using the same method as ASPE used in previous estimates of ACA-related coverage.^8^

Medicaid enrollment estimates are state-reported counts of unduplicated individuals enrolled in the state’s Medicaid program through the Medicaid Budget and Expenditure System (MBES). The most recent Medicaid enrollment data are from September 2023. In mid-2023 states began returning to standard renewal operations with the end of the FFCRA Medicaid continuous enrollment condition. Disenrollments due to this return to standard renewal operations have led to lower enrollment levels in March 2024 than the September 2023 enrollment data presented. For states that have expanded Medicaid, the enrollment data provide specific counts of the number of individuals enrolled in the expansion low-income adult eligibility group, referred to as the “adult group,” with separate totals for those who became newly eligible under the ACA expansion, as well as those who were eligible for coverage prior to the ACA and meet the criteria for the adult group. State Medicaid expenditure reports are generally submitted to CMS within 30 days following the end of each quarter. Some states, however, submit their expenditure reports later; accordingly, these results should be considered preliminary.

Minnesota and New York have also implemented the Basic Health Program (BHP) option under the ACA to cover individuals with incomes between 138-200% FPL. We report BHP enrollment as reported to CMS by the states.

Note that we refer to the estimates below as “2024 estimates” of ACA coverage, though some of the statistics are from late 2023, since those are the most recently available numbers.

Estimates on uninsured rates by state come from the American Community Survey (ACS), the largest national survey of households. The Census Bureau surveys almost 300,000 households each month for the ACS and collects health insurance and demographic data, along with other types of information. Uninsured rates for the full state population of all ages come from the ACS’s public data tables for 2013 and 2022 (the most current year of ACS data available), which we used to compare state-by-state changes in uninsured rates since the implementation of the ACA.^9,10^

## FINDINGS

National ACA-related enrollment for 2014-2024 are presented in Table 1 and Figure 1. More detailed information on each source of coverage is described below. As of February 2024, an estimated 20.5 million consumers had enrolled and effectuated health insurance coverage through the Marketplaces. An estimated 18.6 million newly-eligible adults were enrolled in Medicaid coverage through the adult group created by the ACA expansion based on the most recently available data, as shown in Table 1. An additional estimated 4.6 million people enrolled in Medicaid are adults who meet the criteria for the ACA expansion group but were eligible under previous criteria. The ACA simplified Medicaid enrollment for these individuals and made permanent under federal law some state-specific coverage expansions that pre-dated the ACA (e.g., coverage under a section 1115 demonstration project). To date, 40 states and the District of Columbia have adopted the ACA Medicaid expansion of coverage to adults.

Medicaid enrollment increased in recent years due to states implementing the ACA Medicaid expansion and the continuous enrollment condition in the Families First Coronavirus Response Act of 2020 (FFCRA), which prevented states from disenrolling most Medicaid enrollees enrolled on or after March 18, 2020 as a condition for receiving a temporary increase in their federal Medicaid match rate. This condition ended on March 31, 2023 (under the Consolidated Appropriations Act, 2023) and states began returning to normal Medicaid renewal operations leading to individuals disenrolling from Medicaid (also referenced as Medicaid unwinding), which is reflected in the 2024 enrollment data.

As noted above, two states – Minnesota and New York – have implemented the BHP option under the ACA. In early 2024, BHP enrollment was 1.3 million.

Taken together, these results indicate that overall enrollment in Marketplace coverage, Medicaid expansion, and the Basic Health Program for 2024 was 45 million people, the highest enrollment total since the ACA was enacted. This represents 14.1 million more people enrolled than in 2021 (a 46% increase) and 32.5 million more people enrolled than in 2014 (a 258% increase, or more than triple). Since 2023, 4.7 million more people gained ACA-related coverage, with almost all of the coverage gains from Marketplace.

Table 1 ACA-Related Enrollment: Marketplace, Medicaid, and the Basic Health Program (BHP), 2014-2024

Year | Marketplace Enrollment^*^ | Medicaid Expansion Group, Newly-Eligible^#^ | Medicaid Expansion Group, Non-Newly Eligible | BHP Enrollment^†^ | TOTAL ACA-Related Enrollment
2014 | 6,337,860 | 4,214,218 | 2,047,055 | 0 | 12,599,133
2015 | 10,187,197 | 9,103,944 | 3,002,271 | 358,000 | 22,651,412
2016 | 11,115,044 | 11,135,415 | 3,473,065 | 654,000 | 26,377,524
2017 | 10,330,759 | 12,229,576 | 3,524,856 | 772,000 | 26,857,191
2018 | 10,643,786 | 12,338,135 | 3,305,210 | 798,000 | 27,085,131
2019 | 10,579,744 | 12,201,118 | 3,247,188 | 833,000 | 26,861,050
2020 | 10,673,516 | 12,300,921 | 3,241,535 | 866,000 | 27,081,972
2021 | 11,227,111 | 14,849,998 | 3,890,934 | 961,000 | 30,929,043
2022 | 13,807,669 | 16,781,800 | 4,261,277 | 1,135,190 | 35,985,936
2023 | 15,661,223 | 18,765,611 | 4,648,343 | 1,243,324 | 40,318,501
2024 | 20,524,000^**^ | 18,631,914 | 4,593,306 | 1,309,358 | 45,059,000

Notes

* Marketplace effectuated enrollment figures for 2014 and 2015 are as of 12/31/2014 and 3/31/2015 respectively, versus February coverage as of March 15 for 2016-2021. Marketplace enrollment data for 2014-2015 are lower quality due to the manual payment processing system in place for those years. 2014 and 2015 Marketplace enrollment figures are published here: https://www.cms.gov/Research-Statistics-Data-and-Systems/Statistics-Trends-and-Reports/MarketplaceProducts/Effectuated_Quarterly_Snapshots. February 2016-2023 data are from the CCIIO Enrollment Payment System and beginning in 2017 have been published in the Effectuated Enrollment Snapshot for the respective year.

** Effectuated Marketplace enrollment for 2024 was estimated applying the February 2023 state effectuated rates to the 21.4 million people who made plan selections during the 2024 Open Enrollment Period, https://www.cms.gov/marketplace/resources/forms-reports-other#Health_Insurance_Marketplaces.

# Medicaid enrollment data, 2014-2021, are from the February monthly enrollment (ever enrolled during the month) for the expansion adult eligibility group, as reported by states through the Medicaid Budget and Expenditure System (MBES). 2022-2024 Medicaid enrollment data are from September 2021, September 2022, September 2023 monthly enrollment reports respectively, as this is the most recent available monthly enrollment count from MBES. Published reports and detailed data information for Medicaid enrollment data, including caveats, can be found at: https://www.medicaid.gov/medicaid/national-medicaid-chip-program-information/medicaid-chip-enrollment-data/medicaidenrollment-data-collected-through-mbes/index.html

† BHP programs did not start until 2015. BHP enrollment data are based on average monthly (for Minnesota) or quarterly (for New York) projected enrollment submitted by the states to CMS in advance of the applicable quarter and are rounded to the nearest thousand. BHP enrollment data for 2021 is through May 2021. BHP enrollment data for 2022 is through March 2022. BHP enrollment data for 2023 is through February 2023. BHP enrollment data for 2024 is through February 2024.

Figure 1 ACA-Related Enrollment: Marketplace, Medicaid Expansion, and the Basic Health Program, 2014-2024

Figure 1 is a stacked bar graph that shows ACA-related enrollment of Marketplace, the previously eligible Medicaid expansion group, the newly-eligible Medicaid expansion group, and Basic Health Program from 2014 to 2024. Total ACA-related enrollment increased from 2014 to 2024.

Table 2 presents the most recent state-level enrollment estimates of Marketplace and Medicaid expansion coverage. Table 3 presents uninsured rates in 2013 (before the ACA) and 2022 (the most recent state-level uninsured data). Figure 2 provides a visual summary of the change in the uninsured rate in each state. Nationally, the uninsured rate decreased 6.5 percentage points (from 14.5% to 8.0%) from 2014 to 2022. All states experienced reductions in their uninsured rates, with 12 states – California, Indiana, Kentucky, Louisiana, Michigan, New Hampshire, New Mexico, New York, Oregon, Rhode Island, Washington, and West Virginia, and the District of Columbia, all of which expanded Medicaid – reducing their uninsured rate by at least half. The uninsured rate in 2022 varied widely across the country. Massachusetts had the lowest uninsured rate at 2.4% and experienced one of the smaller relative reductions under the ACA because it had already implemented large coverage expansions prior to 2014. Texas, which has not expanded Medicaid, had the highest uninsured rate in both 2013 (22.1%) and 2022 (16.6%). State decisions regarding the ACA Medicaid expansion are a main driver of variability in coverage rates across states. The Census Bureau’s gold-standard estimates of the uninsured population, which come from the ACS, are not yet available for 2023.

Table 2 Marketplace Enrollment and Medicaid Expansion Enrollment by State

State | Marketplace Plan Selections January 2024^*^ | Marketplace Effectuated Enrollment February 2024^+^ | Medicaid Expansion Newly Eligible September 2023^#^ | Medicaid Expansion Non-Newly Eligible September 2023^#^ | Total ACA-Related Coverage
Alabama | 386,195 | 369,000 | N/A | N/A | 369,000
Alaska | 27,464 | 26,000 | 68,692 | N/A | 94,692
Arizona | 348,055 | 330,000 | 129,676 | 523,245 | 982,921
Arkansas | 156,607 | 143,000 | 244,108 | 9,146 | 396,254
California | 1,784,653 | 1,736,000 | 5,151,950 | 29,935 | 6,917,885
Colorado | 237,106 | 212,000 | 544,038 | 7,667 | 763,705
Connecticut | 129,000 | 125,000 | 334,664 | 31,308 | 490,972
Delaware | 44,842 | 43,000 | 14,652 | 80,957 | 138,609
District of Columbia | 14,799 | 12,000 | 87,379 | 43,975 | 143,354
Florida | 4,211,902 | 4,060,000 | N/A | N/A | 4,060,000
Georgia | 1,305,114 | 1,250,000 | N/A | N/A | 1,250,000
Hawaii | 22,170 | 21,000 | 28,000 | 143,705 | 192,705
Idaho | 103,783 | 101,000 | 83,833 | 0 | 184,833
Illinois | 398,814 | 362,000 | 916,458 | 81,457 | 1,359,915
Indiana | 295,772 | 282,000 | 581,737 | 0 | 863,737
Iowa | 111,423 | 108,000 | 186,569 | 22,521 | 317,090
Kansas | 171,376 | 163,000 | N/A | N/A | 163,000
Kentucky | 75,317 | 68,000 | 593,558 | 0 | 661,558
Louisiana | 212,493 | 207,000 | 737,762 | 0 | 944,762
Maine | 62,586 | 60,000 | 91,408 | 23,886 | 175,294
Maryland | 213,895 | 202,000 | 455,948 | 0 | 657,948
Massachusetts | 311,199 | 277,000 | 0 | 463,523 | 740,523
Michigan | 418,100 | 399,000 | 975,567 | 60,833 | 1,435,400
Minnesota^1^ | 135,001 | 130,000 | 307,001 | 0 | 522,496
Mississippi | 286,410 | 272,000 | N/A | N/A | 272,000
Missouri | 359,369 | 345,000 | 343,168 | 0 | 688,168
Montana | 66,336 | 64,000 | 94,731 | 0 | 158,731
Nebraska | 117,882 | 111,000 | 80,692 | 1,898 | 193,590
Nevada | 99,312 | 96,000 | 374,633 | 0 | 470,633
New Hampshire | 65,117 | 63,000 | 60,642 | 425 | 124,067
New Jersey | 397,942 | 386,000 | 736,843 | 0 | 1,122,843
New Mexico | 56,472 | 61,000 | 268,125 | 0 | 329,125
New York^1^ | 288,681 | 270,000 | 417,302 | 2,078,789 | 3,989,954
North Carolina | 1,027,930 | 987,000 | N/A | N/A | 987,000
North Dakota | 38,535 | 37,000 | 29,964 | 1,501 | 68,465
Ohio | 477,793 | 463,000 | 901,967 | 238 | 1,365,205
Oklahoma | 277,436 | 265,000 | 303,033 | 0 | 568,033
Oregon | 145,509 | 137,000 | 608,684 | 111,016 | 856,700
Pennsylvania | 434,571 | 422,000 | 1,024,336 | 61,267 | 1,507,603
Rhode Island | 36,121 | 36,000 | 97,376 | N/A | 133,376
South Carolina | 571,175 | 566,000 | N/A | 0 | 566,000
South Dakota | 52,974 | 51,000 | 10,164 | N/A | 61,164
Tennessee | 555,103 | 529,000 | N/A | N/A | 529,000
Texas | 3,484,632 | 3,300,000 | N/A | N/A | 3,300,000
Utah | 366,939 | 357,000 | 111,402 | 998 | 469,400
Vermont | 30,027 | 29,000 | 0 | 79,221 | 108,221
Virginia | 400,058 | 385,000 | 739,411 | 0 | 1,124,411
Washington | 272,494 | 263,000 | 688,514 | 19,949 | 971,463
West Virginia | 51,046 | 48,000 | 207,927 | 0 | 255,927
Wisconsin | 266,327 | 257,000 | N/A | N/A | 257,000
Wyoming | 42,293 | 41,000 | N/A | N/A | 41,000
Guam | N/A | N/A | N/A | 6,188 | 6,188
Puerto Rico | N/A | N/A | N/A | 695,102 | 695,102
Virgin Islands | N/A | N/A | N/A | 14,556 | 14,556
Total | 21,446,150 | 20,524,000 | 18,631,914 | 4,593,306 | 45,059,000

Notes:

* 2024 plan selections from states with HealthCare.gov Marketplaces for the Open Enrollment Period of November 1, 2023 to January 16, 2024. Dates through which data are reported vary for State Based Marketplaces. https://www.cms.gov/marketplace/resources/forms-reports-other#Health_Insurance_Marketplaces. State totals do not add up due to rounding.

+ Effectuated Marketplace enrollment for 2024 was estimated applying the February 2023 state effectuated rates to the 21.4 million people who signed-up for coverage during the 2024 Open Enrollment Period, https://www.cms.gov/marketplace/resources/forms-reports-other#Health_Insurance_Marketplaces.

# Medicaid Data: September 2023 enrollment of newly eligible population as reported on the CMS-64. Awaiting state reporting, enrollment reasonableness review is in progress. Enrollment only applicable for states that have expanded their Medicaid programs to adults with incomes up to 138% FPL (the “adult group”). For the states that have not expanded Medicaid their enrollment is noted as “N/A.” Massachusetts and Vermont already offered subsidized coverage to those with incomes below 138% FPL, so they are listed as having 0 newly-eligible adults, even though they have implemented the ACA’s Medicaid expansion.

1 Minnesota total includes an estimated 85,495 Basic Health Plan enrollees as of February 2024.

2 New York total includes an estimated 1,223,863 Basic Health Plan enrollees as of February 2024.

Table 3 Uninsured Rates for 2013 and 2022

State | Uninsured Rate %^^^
State | 2013 | 2022
Alabama | 13.6 | 8.8
Alaska | 18.5 | 11.0
Arizona | 17.1 | 10.3
Arkansas | 16.0 | 10.1
California | 17.2 | 6.5
Colorado | 14.1 | 7.1
Connecticut | 9.4 | 5.2
Delaware | 9.1 | 5.6
District of Columbia | 6.7 | 2.9
Florida | 20.0 | 11.2
Georgia | 18.8 | 11.7
Hawaii | 6.7 | 3.5
Idaho | 16.2 | 8.2
Illinois | 12.7 | 6.6
Indiana | 14.0 | 7.0
Iowa | 8.1 | 4.5
Kansas | 12.3 | 8.6
Kentucky | 14.3 | 5.6
Louisiana | 16.6 | 6.9
Maine | 11.2 | 6.6
Maryland | 10.2 | 6.1
Massachusetts | 3.7 | 2.4
Michigan | 11.0 | 4.5
Minnesota | 8.2 | 4.5
Mississippi | 17.1 | 10.8
Missouri | 13.0 | 8.6
Montana | 16.5 | 8.3
Nebraska | 11.3 | 6.7
Nevada | 20.7 | 11.1
New Hampshire | 10.7 | 4.9
New Jersey | 13.2 | 6.8
New Mexico | 18.6 | 8.2
New York | 10.7 | 4.9
North Carolina | 15.6 | 9.3
North Dakota | 10.4 | 6.4
Ohio | 11.0 | 5.9
Oklahoma | 17.7 | 11.7
Oregon | 14.7 | 6.0
Pennsylvania | 9.7 | 5.3
Rhode Island | 11.6 | 4.2
South Carolina | 15.8 | 9.1
South Dakota | 11.3 | 8.1
Tennessee | 13.9 | 9.3
Texas | 22.1 | 16.6
Utah | 14.0 | 8.1
Vermont | 7.2 | 3.9
Virginia | 12.3 | 6.5
Washington | 14.0 | 6.1
West Virginia | 14.0 | 5.9
Wisconsin | 9.1 | 5.2
Wyoming | 13.4 | 11.5
Total | 14.5 | 8.0

^ Uninsured Rates: American Community Survey, “Health Insurance Coverage Status and Type of Coverage by State and Age for All People”, 2013-2022: https://www.census.gov/data/tables/time-series/demo/health-insurance/acs-hi.2013.html.

Figure 2 Relative Reduction in the Uninsured Rate by State, 2013 to 2022

Uninsured Rates: American Community Survey, “Health Insurance Coverage Status and Type of Coverage by State and Age for All People”, 2013-2022: https://www.census.gov/data/tables/time-series/demo/health-insurance/acs-hi.2013.html.

Figure 2 is a map of the United States that shows relative reduction in the uninsured rate by state from 2013 to 2022. The 4 shades represent ranges of -14% to -40%, -40% to -45%, -45% to -50%, and -50% to -65%.

## CONCLUSION

The ACA’s multiple programs have led to an historic expansion of health coverage, with an estimated 45 million people currently enrolled in coverage related to the law. Gains have accelerated since 2021, concurrent with legislative and administrative efforts to expand health coverage. These efforts include: enhanced subsidies for Marketplace coverage under the American Rescue Plan and later extended by the Inflation Reduction Act; robust outreach efforts to sign up eligible individuals for coverage; special enrollment periods for COVID, consumers with household incomes at or below 150 percent of the Federal Poverty Level and those disenrolled from Medicaid due to the end of the continuous enrollment condition that had been in place during the COVID-19 public health emergency; and state adoption of ACA Medicaid expansions.

Of note, estimates of ACA-related coverage presented in this Issue Brief are a conservative estimate of the law’s impact on health insurance coverage for several reasons. First, the effectuated enrollment estimate for the Marketplace is a more conservative estimate than plan selections. Second, the total does not include the provision of the ACA that took effect in 2010 allowing young adults to remain on their parents’ plans (e.g., employer sponsored insurance) until age 26, which previous research estimated led to more than 2 million young adults gaining insurance within the first year that it was in effect.^11^ Third, the streamlining of Medicaid applications, enhanced outreach, and expanded eligibility led to increased enrollment even among children and parents who were eligible for Medicaid through traditional pre-expansion pathways, a phenomenon referred to as the “welcome mat” effect.^12^ Thus, 45 million likely underestimates the total effect of the ACA.

## REFERENCES

1 As amended by the Health Care and Education Reconciliation Act of 2010.
2 Census Bureau, American Community Survey Tables for Health Insurance Coverage Status and Type of Coverage by State and Age for All People. Accessed at: https://www.census.gov/data/tables/time-series/demo/health-insurance/acs-hi.2013.html.
3 Census Bureau, American Community Survey Tables for Health Insurance Coverage Status and Type of Coverage by State and Age for All People. Accessed at https://www.census.gov/data/tables/time-series/demo/health-insurance/acs-hi.2022.html#list-tab-776654388
4 National Uninsured Rate Remains Largely Unchanged at 7.7 Percent in the Third Quarter of 2023. (Issue Brief No. HP-202402). Office of the Assistant Secretary for Planning and Evaluation, U.S. Department of Health and Human Services. February 2024. Accessed at: https://www.aspe.hhs.gov/reports/national-uninsured-rate-q3-2023
5 Health Insurance Marketplaces 2024 Open Enrollment Report. CMS. March 2024. Accessed at: https://www.cms.gov/marketplace/resources/forms-reports-other#Health_Insurance_Marketplaces
6 Health Insurance Marketplaces 2024 Open Enrollment Report. CMS. March 2024. Accessed at: https://www.cms.gov/marketplace/resources/forms-reports-other#Health_Insurance_Marketplaces
7 Health Coverage Under the Affordable Care Act: Enrollment Trends and State Estimates. Office of the Assistant Secretary for Planning and Evaluation, U.S. Department of Health and Human Services. March 2023. Accessed at: https://aspe.hhs.gov/reports/current-health-coverage-under-affordable-care-act.
8 Health Coverage Under the Affordable Care Act: Enrollment Trends and State Estimates. Office of the Assistant Secretary for Planning and Evaluation, U.S. Department of Health and Human Services. March 2023. Accessed at: https://aspe.hhs.gov/reports/current-health-coverage-under-affordable-care-act Lee A, Chu RC, Peters C, and Sommers BD. Health Coverage Changes Under the Affordable Care Act: End of 2021 Update. (Issue Brief No. HP-2022-17). Office of the Assistant Secretary for Planning and Evaluation, U.S. Department of Health and Human Services. April 2022. Accessed at: https://aspe.hhs.gov/reports/health-coverage-changes-2021-update
9 Census Bureau, American Community Survey, Health Insurance Coverage Status and Type of Coverage by State and Age for All People. Accessed at: https://www.census.gov/data/tables/time-series/demo/health-insurance/acs-hi.2013.html.
10 Lee A, Ruhter J, Bosworth A, Peters C, De Lew N, Sommers BD. Changes in Health Insurance Coverage from 2019 to 2021: Geographic and Demographic Patterns in the Uninsured Rate (Issue Brief No. HP-2023-01). Office of the Assistant Secretary for Planning and Evaluation, U.S. Department of Health and Human Services. January 2023. Accessed at: https://aspe.hhs.gov/reports/changes-health-insurance-coverage-2019-2021.
11 Uberoi, N., Finegold, K., & Gee, E. (March 3, 2016). Health insurance coverage and the Affordable Care Act, 2010-2016. Washington (DC): Department of Health and Human Services, Office of the Assistant Secretary for Planning and Evaluation. Accessed at: https://aspe.hhs.gov/system/files/pdf/187551/ACA2010-2016.pdf.
12 Hudson, J. and Moriya, A. “Medicaid Expansion for Adults Had Measurable ‘Welcome Mat’ Effects on their Children”. Health Affairs, September 2017.

* A total of 21.4 million consumers made plan selections as of January 2024 and an estimated 20.5 million consumers effectuated enrollment (paid a premium or otherwise completed enrollment) as of February 2024. See notes for Table 1 for more information.

† North Carolina’s expansion was implemented December 2023.

‡ Individuals with incomes above 400% FPL can purchase coverage through the Marketplaces but did not originally qualify for premium tax credit subsidies. Under the American Rescue Plan and extended by the Inflation Reduction Act, individuals with incomes above 400% FPL are now potentially eligible for subsidies.

§ The ACA established a minimum Medicaid eligibility level of 133% FPL for children, pregnant women, and adults as of January 2014. States may elect to cover adults with incomes up to 133% FPL in their State Medicaid program, in accordance with the Supreme Court decision in NFIB v. Sebelius (2012). The low-income adult group also has standard income disregard of five percentage points of the FPL, which effectively raises this limit to 138% FPL. As of March 2024, 40 states and the District of Columbia have adopted the Medicaid expansion for low-income adults.