# References

AcademyHealth, "Medicaid Data Learning Network," webpage, July 2023. As of August 7, 2023: https://academyhealth.org/about/programs/medicaid-data-learning-network
APCD Council, "Claims Data Release Rules," webpage, undated-a. As of August 7, 2023: https://www.apcdcouncil.org/claims-data-release-rules
APCD Council, "Interactive State Report Map," webpage, undated-b. As of August 7, 2023: https://www.apcdcouncil.org/state/map
APCD Council, National Association of Health Data Organizations, and the University of New Hampshire, "APCD Common Data Layout," webpage, February 2021. As of August 7, 2023: https://www.apcdcouncil.org/apcd-common-data-layout-apcd-cdl
ASPE—See Office of the Assistant Secretary for Planning and Evaluation.
Burke Laura G., Zhou Xiner, Boyle Katherine L., Orav E. John, Bernson Dana, Hood Maria-Elena, Land Thomas, Bharel Monica, and Frakt Austin B., "Trends in Opioid Use Disorder and Overdose Among Opioid-Naive Individuals Receiving an Opioid Prescription in Massachusetts from 2011 to 2014," Addiction, Vol. 115, No. 3, 2020.
Carman Katherine Grace, and Dworsky Michael, Transitions in Coverage: Colorado 2011–2017 (HP-HAC-3–3a), RAND Corporation, PR-A1552–2, 2020.
Carman Katherine Grace, Dworsky Michael, Heins Sara E., Qureshi Nabeel, Schwam Daniel, Shelton Shoshana R., and Whaley Christopher M., State All Payer Claims Databases: Understanding the Current Landscape and Challenges to Use, RAND Corporation, PRA1857–1, May 2022.As of August 7, 2023: https://aspe.hhs.gov/reports/all-payer-claims-data-bases-2022
Cefalu William T., Dawes Daniel E., Gavlak Gina, Goldman Dana, Herman William H., Karen Van Nuys Alvin C. Powers, Taylor Simeon I., and Yatvin Alan L., "Insulin Access and Affordability Working Group: Conclusions and Recommendations," Diabetes Care, Vol. 41, No. 6, 2018.
Chen Chen, Haupert Spencer R., Zimmermann Lauren, Shi Xu, Fritsche Lars G., and Mukherjee Bhramar, "Global Prevalence of Post COVID-19 Condition or Long COVID: A MetaAnalysis and Systematic Review," Journal of Infectious Diseases, Vol. 226, No. 9, 2022.
Colorado Center for Improving Value in Health Care, "COVID-19 Testing Price Variation," webpage, 2023. As of May 25, 2023: https://civhc.org/covid-19/covid-19-testing-price-variation/
Colorado Office of Saving People Money on Health Care, Report on Long COVID in Colorado, December 2022.
Cutler David M., "The Costs of Long COVID," JAMA Health Forum, Vol. 3, No. 5, 2022.
Haakenstad Annie, Summer Sherburne Hawkins Lydia E. Pace, and Cohen Jessica, “RuralUrban Disparities in Colonoscopies After the Elimination of Patient Cost-Sharing by the Affordable Care Act," Preventive Medicine, Vol. 129, 2019.
Haas Ann, Elliott Marc C., Dembosky Jacob W., Adams John L., Wilson-Frederick Shondelle M., Mallett Joshua S., Gaillot Sarah, Haffer Samuel C., and Haviland Amelia M., "Imputation of Race/Ethnicity to Enable Measurement ofHEDIS Performance by Race/Ethnicity," Health Services Research, Vol. 54, No. 1, 2019.
Laxy Michael, Zhang Ping, Benoit Stephen R., Imperatore Giuseppina, Cheng Yiling J., Gregg Edward W., Yang Shuang, and Shao Hui, "Trends in Total and Out-of-Pocket Payments for Insulin Among Privately Insured U.S. Adults with Diabetes from 2005 to 2018," Diabetes Care, Vol. 44, No. 10, 2021.
Little Roderick J. A., and Rubin Donald B., Statistical Analysis with Missing Data, 3rd ed., Vol. 793, Wiley, 2019.
Logue Jennifer K., Franko Nicholas M., McCulloch Denise J., McDonald Dylan, Magedson Ariana, Wolf Caitlin R., and Chu Helen Y., "Sequelae in Adults at 6 Months After COVID19 Infection," JAMA Network Open, Vol. 4, No. 2, 2021.
McAvey K., "Realizing the Promise of All Payer Claims Databases: A Federal and State Action Plan," Manatt, December 2022.
McCarthy Douglas, State All-Payer Claims Databases: Tools for Improving Health Care Value—Part 1: How States Establish an APCD and Make It Functional, the Commonwealth Fund, December 2020.
Miller Patrick B., Love Denise, Sullivan Emily, Porter Jo, and Costello Amy, "All-Payer Claims Databases: An Overview for Policymakers," University of New Hampshire, 2010. As of August 10, 2023: https://scholars.unh.edu/cgi/viewcontent.cgi?article=1127&context=ihpp
NIH RePORTER, "Effect of a State-Level Co-Payment Cap for Insulin on Utilization and Glycemic Control," Project Number 1R03HS029202–01, webpage, undated. As of September 21, 2023: https://reporter.nih.gov/search/rlURWlyhoUeIHARd0BQYLw/project-details/10571244
Office of the Assistant Secretary for Planning and Evaluation, Building Data Capacity for Patient-Centered Outcomes Research, Office of the Secretary Patient-Centered Outcomes Research Trust Fund Strategic Plan: 2020–2029, U.S. Department of Health and Human Services, September 2022. As of August 7, 2023: https://aspe.hhs.gov/os-pcortf-strategic-plan-2020-2029
Office of the Secretary, Department of Health and Human Services, "Confidentiality of Substance Use Disorder (SUD) Patient Records," Federal Register, Vol. 87, No. 231, December 2, 2022.
Oregon Health Authority, Primary Care Spending in Oregon 2020, May 2022. RAND Corporation, "RAND Bayesian Improved Surname Geocoding," webpage, undated. As of August 10, 2023: https://www.rand.org/health-care/tools-methods/bisg.html
Robert Wood Johnson Foundation, "Health Data for Action (Data Access Award]: Leveraging Health Data for Actionable Insight," June 2023. As of August 10, 2023: https://anr.rwjf.org/viewCfp.do?cfpld=1696&cfp0verviewld=
Silva Gabriella C., Trivedi Amal N., and Gutman Roee, "Developing and Evaluating Methods to Impute Race/Ethnicity in an Incomplete Dataset," Health Services and Outcomes Research Methodology, Vol. 19, No. 2–3, 2019.
Sorbero Melony E., Euller Roald, Kofner Aaron, and Elliott Marc N., Imputation of Race and Ethnicity in Health Insurance Marketplace Enrollment Data, 2015–2022 Open Enrollment Periods, RAND Corporation, RR-A1853–1, 2022.As of August 10, 2023: https://www.rand.org/pubs/research_reports/RRA1853–1.html
State All Payer Claims Databases Advisory Committee, State All Payer Claims Databases Advisory Committee Report with Recommendations Under Section 735 of the Employee Retirement Income Security Act of1974, 2021. As of August 10, 2023: https://www.dol.gov/sites/dolgov/files/ebsa/about-ebsa/about-us/state-all-payerclaims-databases-advisory-committee/final-report-and-recommendations-2021.pdf
Steenland Maria, Sinaiko Anna, Glynn Amy, Fitzgerald Therese, and Cohene Jessica, "The Effect of the Affordable Care Act on Patient Out-of- Pocket Cost and Use of Preventive Cancer Screenings in Massachusetts," Preventive Medicine Reports, Vol. 15, 2019.
Subramanian Anuradhaa, Nirantharakumar Krishnarajah, Hughes Sarah, Myles Puja, Williams Tim, Gokhale Krishna M., Taverner Tom, Joht Singh Chandan Kirsty Brown, Simms-Williams Nikita, , "Symptoms and Risk Factors for Long C0VID in Non-Hospitalized Adults," Nature Medicine, Vol. 28, No. 8, 2022.
Taylor Erin Audrey, Khodyakov Dmitry, Buttorff Christine, Dusetzina Stacie B., Rao Preethi, Predmore Zachary, Cefalu Matthew, Cooke Catherine E., Wilks Asa, Zhang Shiyuan, Dalton Sarah, and Martineau Monique, Part D Senior Savings Model: Model Reach and Scope, Centers for Medicare & Medicaid Services, RAND Corporation, EP-69078, 2022. As of July 25,2023: https://www.rand.org/pubs/external_publications/EP69078.html
Thompson Ellen J., Williams Dylan M., Walker Alex J., Mitchell Ruth E., Niedzwiedz Claire L., Yang Tiffany C., Huggins Charlotte F., Kwong Alex S. F., Silverwood Richard J.,, "Long C0VID Burden and Risk Factors in 10 UK Longitudinal Studies and Electronic Health Records," Nature Communications, Vol. 13, No. 3528, 2022.
U.S. Centers for Disease Control and Prevention, "Long COVID or Post-COVID Conditions," webpage, updated December 16, 2022. As of May 8, 2023: https://www.cdc.gov/coronavirus/2019-ncov/long-term-effects/index.html
Whaley Christopher M., Briscombe Brian, Kerber Rose, O’Neill Brenna, and Kofner Aaron, Nationwide Evaluation of Health Care Prices Paid by Private Health Plans: Findings from Round 3 of an Employer-Led Transparency Initiative, RAND Corporation, RR-4394RWJ, 2020.AS of July 25, 2023: https://www.rand.org/pubs/research_reports/RR4394.html