# Acknowledgments

We are grateful to the stakeholders who shared their perspectives included in this report, including leaders from state APCDs in Oregon, Utah, Colorado, Virginia, Maryland, and Massachusetts; data vendors that provide services to state APCDs; and researchers. Kerry Reynolds at RAND provided feedback related to connections between APCDs and patient-centered outcomes research, and Rosa Maria Torres at RAND provided helpful administrative assistance with the report. Kevin McAvey of Manatt Health served as a consultant on the project and shared comments on this report. Valuable feedback on this report was provided by ASPE. We thank Petra Rasmussen, Christine Eibner, and Paul Koegel of the RAND Corporation for reviewing this report.