# Summary

## Background and Approach

All payer claims databases (APCDs) collect data on health insurance enrollment and claims across public and private insurance plans within a single state. The further development of APCDs, including steps to facilitate use cases that combine data from multiple state APCDs, could play an important role in building data capacity for patient-centered outcomes research (PCOR). The Office of the Assistant Secretary for Planning and Evaluation (ASPE) contracted with the RAND Corporation to identify challenges and strategies for leveraging APCDs for patient-centered outcomes research and multi-state use cases—with a focus on missing data, missing populations, and data linkages. A series of semistructured discussions and focus groups with stakeholders were held, including state APCD leaders, data vendors that provide services to state APCDs, and researchers who have used multiple state APCDs, and a draft common data application and two research plans for use cases relying on multi-state APCD data were developed.

## Key Findings

All stakeholders indicated that APCDs have the potential to be used for patient-centered outcomes research. Their ideas regarding the potential use of APCDs were aligned with goals included in the Strategic Plan from the Office of the Secretary Patient-Centered Outcomes Research Trust Fund, especially in expanding longitudinal data resources (through data standards and linkages) to generate evidence on diverse patient populations (ASPE, 2022).

Stakeholders, however, noted major limitations related to missing data, missing populations, and opportunities to further expand the use of APCDs for patient-centered outcomes research. Major challenges highlighted by stakeholders included missing information about race and ethnicity, missing information on individuals covered by self-insured plans regulated under the Employee Retirement Income Security Act (ERISA), and missing information on individuals without insurance or covered by federal and military insurance (i.e., Federal Employees Health Benefits program and TRICARE) and other health care programs (i.e., the Veterans Health Administration and Indian Health Service). Data linkages between APCDs and other administrative data were identified as an opportunity to address some of these limitations (e.g., fill in missing information about race and ethnicity) and address research questions that cannot be fully addressed using the data available in APCDs alone (e.g., questions on the outcomes and effectiveness of specific health care interventions and/or requiring context-specific data, such as opioid overdoses and maternal health).

The use of APCDs from multiple states was recognized as an approach with significant potential benefits, including for policy evaluations, studying small population subgroups, and rare conditions. Although some multi-state use cases have been successfully completed, stakeholders mentioned barriers, including the burden of submitting separate data requests to multiple states, differences across states in allowed uses of the data, variation across states in file layout and data structures, and differences in intake and data processing procedures that could limit comparability even between states that receive similar files from payers and store data in similar layouts. Some researchers also noted that the complexity and expense of a multi-state analysis might deter them from pursuing such work in the future given missing populations (e.g., limited information on ERISA plans) and uncertainty about the comparability of data across states.

## Facilitating Use of APCDs for Patient-Centered Outcomes Research and Multi-State Use Cases

Below, we summarize issues identified by the stakeholders and possible actions suggested by the stakeholders to facilitate the expanded use of APCDs. All items in this table reflect perspectives mentioned by stakeholders during discussions (Table S.1). More detailed discussion of issues and possible actions is presented in Chapter 4 of this report.

Table S.1 Stakeholder-Suggested Options to Facilitate Patient-Centered Outcomes Research and Multi-State Analyses Using APCDs

Issues | Possible Actions (Implementer)
Missing race and ethnicity data in APCDs | - Link APCDs and hospital admission records, vital records, or other public health data (states)^a^; - Probabilistically impute this information in APCDs (states)^a^
Confusion related to 42 Code of Federal Regulations Part 2 and the sharing of substance use disorder data | - Clarify and improve communication to payers (federal government or states)^a^
Missing populations: Access to ERISA plan data | - Offer more outreach to ERISA plans, with customized reporting and benchmarks to encourage voluntary data submission (states)^a^; - Create legislation or regulation to require ERISA submission to state APCDs (federal government)^a^; - Collect ERISA plan data in a nationwide, federally supported database, which could then be shared with states and researchers (federal government)^c^
Missing populations: Access to federal health plan and health system data | - Create a dataset with these data that could be shared with states and researchers (federal government)^c^
Missing populations: Lack of data on the uninsured | - Link APCDs with hospital records, electronic health records, and other datasets to capture information on patients without continuous insurance coverage or those who self-pay for some care (states)^a^
Missing populations: Timely access to Medicare data | - Establish more-regular Medicare data submission to APCDs, potentially including using the All Payer Claims Database Common Data Layout (APCD-CDL^™^) as a format for regular submission of Medicare data to state APCDs (states working with federal government)^b^
Uncertainty regarding what is included in APCD data across states and how these data can be used | - Gather and centrally disseminate current information about what populations and data are included in each state’s APCD and what uses are allowed (states)^a^; - Define metrics for APCD data completeness and support state reporting of these metrics (federal government working with states)^a^
Barriers to pursuing multi-state APCD collaborations and research | - Refine and share a draft common data application (federal government)^a^; - Produce and maintain a mapping between state APCD data layouts and the APCD-CDL^™^ (federal government)^a^; - Develop open-source software for APCD data intake and processing to help make data more comparable across states (federal government)^a^; - Create a learning network for users of multiple states’ APCD data (federal government or states)^a^; - Expand federal funding opportunities to encourage multi-state APCD work (federal government)^a^; - Expand federal funding opportunities to encourage linking of APCDs to other data to conduct PCOR studies (federal government)^a^; - Incentivize states to harmonize APCD datasets and data layouts, either with financial support or as a requirement to access federal health plan data (federal government)^b^
Lack of national or multi-state APCD | - Encourage states to submit their own APCD data to a federal data provider for purposes of building a multi-state resource (federal government)^c^

NOTE: The table lists issues identified by stakeholders and their suggestions of possible actions to address those issues. When possible, a party that might take a given action is identified in parentheses.

a These actions do not require data collection or data-sharing from the federal government.

b These actions potentially require data collection or data-sharing from the federal government but do not involve submission of state APCD data to a federally supported multi-state database.

c These actions involve establishment of a federally supported multi-state database.

## Conclusions and Next Steps

APCDs can be used to conduct patient-centered outcomes research that addresses a range of questions important to patients, caregivers, clinicians, and policymakers. The use of data from multiple state APCDs may further facilitate these studies by providing control groups to evaluate state policies and allowing the examination of population subgroups and rare conditions. However, many barriers to the use of APCDs in PCOR studies and multi-state use cases need to be addressed. This report explores these challenges and potential paths forward to facilitate the use of APCDs for patient-centered outcomes research and multi-state use cases.