# Disclaimer

The findings and conclusions in this project report are those of the authors and do not necessarily represent the official position of HHS.