# About This Project Report

State all payer claims databases (APCDs) collect data on health insurance enrollment and claims across public and private insurance plans within a single state. The further development of APCDs, including steps to facilitate use cases that combine data from multiple state APCDs, could play an important role in building data capacity for patient-centered outcomes research (PCOR). However, the utility of APCDs for PCOR studies has been limited by missing data and by missing populations not captured in state APCDs. Differences in APCD data completeness and processing across states, differences in the data available for release, lack of harmonized data, and the lack of clear information about these state-to-state variations also limit multi-state applications of APCD data, including for patient-centered outcomes research.

The U.S. Department of Health and Human Services (HHS), other federal government departments, and Congress have indicated interest in improving the utility of state APCDs for research. The Office of the Assistant Secretary for Planning and Evaluation (ASPE) contracted with the RAND Corporation to conduct discussions with state APCD leaders and other stakeholders about the uses of APCDs for patient-centered outcomes research and multi-state analyses, including barriers to these uses of APCD data and opportunities to address these barriers.

This research was funded by the Office of the Secretary Patient-Centered Outcomes Research Trust Fund through ASPE (task order # HHSP23337008T under contract #HHSP233201500038I) and carried out within the Payment, Cost, and Coverage Program in RAND Health Care.