# Looking Forward

Increased interest from states in using APCD data for common purposes as well as researchers seeking to leverage the data for PCOR studies and multi-state analyses, presents opportunities for collective action. As we noted in the introduction to the second RAND report,^xvii^ OS-PCORTF has funded a project to develop and pilot a prototype database from several volunteer states with a goal of providing greater transparency into the outcomes, effectiveness, and costs of our health care system, building on a base of health care claims data being collected at the state-level.^xviii^ The project builds on the work of the agency for Healthcare Research and Quality’s (AHRQ) Healthcare Cost and Utilization Project (HCUP) to establish a common data model across state hospital-related discharge databases — an effort that began with a handful of participating states and is now the largest and most comprehensive hospital-based data resource, representing 48 states and the District of Columbia and over 95 percent of all hospital discharges in the U.S. In addition to being an asset to individual states, HCUP is regularly used by health policy analysts to address a wide variety of topics at the national level.

Building a model for a national level APCD is critical to supporting the rigorous and robust research needed to address some of the nation’s most pressing health care challenges, including in ambulatory care settings. ASPE hopes this report and related efforts will provide a foundation for coordination and collaboration across stakeholders to further advance APCD infrastructure and the use of APCD data in research and policy.

xvii ASPE staff, Carman K, Dworsky M, Heins, Quershi N S, Schwam D, Shelton S, Whaley C Linking State Health Care Data to Inform Policymaking: Opportunities and Challengeshttps://aspe.hhs.gov/sites/default/files/documents/96f34fd0474b3da4884836c4341f1bbe/Linking-State-Health-Care-Data.pdf (https://aspe.hhs.gov/sites/default/files/documents/96f34fd0474b3da4884836c4341f1bbe/Linking-StateHealth-Care-Data.pdf)

xviii https://aspe.hhs.gov/panoramic-view-patient-care-data-innovations-kages