# Background

This cover memo is a companion piece to the report which follows, “State All Payer Claims Databases: Identifying challenges and opportunities for conducting patient-centered outcomes research and multi-state studies,” the third in a series of reports commissioned by the Office of the Assistant Secretary for Planning and Evaluation (ASPE) from the RAND Corporation addressing state all payer claims databases (APCDs). APCDs include medical, pharmacy, and dental claims, as well as enrollment and provider files collected from private and public payers by states, usually as part of a State mandate.^i^ As of January 1, 2023, a total of 23 states have either a mandatory APCD (with statutorily-mandated reporting from covered payers) or a voluntary APCD,^ii^ and an additional eight states are currently developing mandatory APCDs.^iii^ APCDs have an important role to play in supporting health services research, informed policy making, and health care system transparency, as they can address the need for, among other things, reliably updated data on health care utilization and the cost of care that can be tracked longitudinally across payers, Their data can also be linked to other databases, which is especially important when considering the social drivers of health.

The first commissioned report, released in June 2021, was prepared to help inform the deliberations of the Department of Labor’s State All Payer Claims Database Advisory Committee, a committee created by the No Surprises Act.^iv,v^ That report provided information on the status of APCDs across the states, how they have been used, and their strengths and limitations (https://aspe.hhs.gov/sites/default/files/private/pdf/265666/apcd-background-report.pdf).^vi^ The second report, released in June 2022, provided additional detail on ACPD data collection and access procedures, further described use cases, and discussed some of the most important challenges associated with operating an APCD and working with APCD data (https://aspe.hhs.gov/sites/default/files/documents/96f34fd0474b3da4884836c4341f1bbe/Linking-State-Health-Care-Data.pdf).^vii^ This third report focuses on issues associated with two particular aspects of APCD research: the use of APCDs to conduct patient-centered outcomes research (PCOR) and the challenges of multi-state APCD research. PCOR aims to generate evidence about the effectiveness of treatments, services, and other health care interventions on the full range of outcomes that patients, caregivers, clinicians, policymakers, and other stakeholders have identified as important. The following report explores the use of APCDs for these two purposes, including presenting findings from a series of discussions with officials at six state APCDs, data vendors, and researchers who have used data from multiple state APCDs; example research plans for two multi-state use case studies; and a prototype data request application that could be used for the purposes of creating a standardized application for requesting APCD data from multiple states.

ASPE’s interest in APCDs is heightened by our charge to coordinate across relevant federal health programs to build data capacity for PCOR, including administering the Office of the Secretary’s Patient-Centered Outcomes Research Trust Fund (OS-PCORTF). Established by the Patient Protection and Affordable Care Act, the PCORTF supports the work of the Patient-Centered Outcomes Research Institute (PCORI), Agency for Healthcare Research and Quality (AHRQ), and the Office of the Secretary of HHS to conduct, disseminate, and expand capacity for PCOR and comparative clinical effectiveness studies (CER), respectively.^viii^ In December 2019, Congress reauthorized the PCORTF through 2029 and expanded the range of outcomes that should be considered in PCOR studies to include the “potential burdens and economic impacts of the utilization of medical treatments, items, and services on different stakeholders and decision-makers respectively. These potential burdens and economic impacts include medical out-of-pocket costs, including health plan benefit and formulary design, non-medical costs to the patient and family, including caregiving, effects on future costs of care, workplace productivity and absenteeism, and healthcare utilization.”^ix^ APCDs address the broad needs emphasized in the 2022 report from the National Academies of Sciences, Engineering, and Medicine, Building Data Capacity for Patient-Centered Outcomes Research: Priorities for the Next Decade, for data that can be tracked over time across jurisdiction and are well-positioned to support the expanded scope of PCOR studies arising from the PCORTF reauthorization. ^x^

However, researchers face a number of challenges in using APCDs for PCOR studies, including multi-state analyses. APCDs are rooted in state legislation, with state governments or their agents determining the content of their APCDs and procedures and authorities for the collection and release of data. Particular studies using APCDs are often legislatively authorized, respond to specific state concerns, focus on health care costs and utilization, and, significantly, are limited to a single state. Having multi-state data would allow for expanded research on relatively rare medical conditions and smaller population subgroups important to assess health equity. Such data would also allow for cross-state comparisons of trends. However, gaining access to data from multiple states can be challenging, and even when access is granted, the data may not be readily usable for regional or national research. For example, data from different states may not share a common format, or critical variables may be defined differently across APCDs. The difficulties in conducting multi-state APCD research are illustrated by the lack of a single multi-state effort among the more than 25 research studies included in the recent APCD Showcase (a collection of research studies, dashboards, and related APCD products from 2022–2023)^xi^.

Given the common interests among states related to the use of APCD data (e.g., setting targets for health care cost growth^xii^ or specifying a target percentage of total health care costs to be devoted to primary care^xiii^ there have been emerging efforts to address these challenges. For example, the APCD Council, an organization of state APCD stakeholders, has developed technical specifications and file layouts for APCD data collection, commonly known as the APCD-CL^xiv^ ^xv^, ’ which has been adopted by some states, especially states newly establishing APCDs^xvi^. However, as discussed in the following RAND report, much work remains to be done to improve the availability, quality, accessibility, and ability to link APCD data for PCOR studies and multi-state analyses.

i https://www.ahrq.gov/data/apcd/index.html#:~:text=All-paver%20claims%20databases%20%28APCDs%29%20are%201arge%20State%20databases.States%2C%20iisuallv%20as%20part%20of%20a%20State%20mandate.

ii Note that California, Washington, and Texas have both voluntary and mandatory efforts, as voluntary efforts were in place prior to mandatory efforts began.

iii https://www.mdclarity.com/blog/all-payer-claims-databases-apcd

iv Consolidated Appropriation Act 2021, Division BB, Title I, Section 115 https://www.congress.gov/116/plaws/publ260/PLAW-116publ260.pdf

v The Act required the Department of Labor to establish an Advisory Committee to produce a report with recommendations for a standardized reporting format for ERISA group health plans to voluntarily report to state APCDs and to offer guidance to the states on the use of the standardized reporting format, The Committee’s report can be found at https://www.dol.gov/agencies/ebsa/about-ebsa/about-us/state-all-payer-claims-databases-advisory-committee,

vi Carman K, Dworsky M, Heins S, Schwam D, Shelton S, Whaley C. The History, Promise and Challenges of State All Payer Claims Databases Background Memo for the State All Payer Claims Database Advisory Committee to the Department of Labor. The RAND Corporation, June 2, 2021. https://aspe.hhs.gov/sites/default/files/private/pdf/265666/apcd-background-report.pdf

vii ASPE staff, Carman K, Dworsky M, Heins, Quershi N S, Schwam D, Shelton S, Whaley C Linking State Health Care Data to Inform Policymaking: Opportunities and Challenges https://aspe.hhs.gov/sites/default/files/documents/96f34fd0474b3da4884836c4341f1bbe/Linking-State-Health-Cares-Data.pdf (https://aspe.hhs.gov/sites/default/files/documents/96f34fd0474b3da4884836c4341f1bbe/Linking-State-Health-Care-Data.pdf)

viii Patient Protection and Affordable Care Act, Publ. L. No. 111–148, 124 Stat. 119 (2010). https://www.govinfo.gov/content/pkg/PLAW-111publ148/html/PLAW-111publ148.htm

ix Further Consolidated Appropriations Act, 2020, Publ. L. No. 116–94, 133 Stat. 2534 (2019). https://www.congress.gov/116/plaws/publ94/PLAW-116publ94.pdf

x Washington, DC: The National Academies Press, https://doi.org/10.17226/26489.

xi https://www.apcdshowcase.org/case-studies?field_category_tid=4&page=2

xii "States Setting Health Care Spending Growth Targets Experienced Accelerated Growth in 2021", Health Affairs Forefront, June 29, 2023. https://www.healthaffairs.org/content/forefront/6-29-angeles-piece

xiii https://www.aafp.org/dam/AAFP/documents/advocacy/payment/apms/BKG-PrimaryCareSpend.pdf

xiv https://www.apcdcouncil.org/apcd-common-data-layout-apcd-cdl%E2%84%A2

xv The State All Payer Claims Data Bases Advisory Committee identified the APCD-CDL as "an immediately available starting point for a uniform data layout for adoption by APCDs" and submitters APCD data. State All Payer Claims Data Bases Advisory Committee Report with Recommendations. https://www.dol.gov/sites/dolgov/files/ebsa/about-ebsa/about-us/state-all-payer-claims-databases-advisory-committee/final-report-and-recommendations-2021.pdf

xvi See, for example, California: https://www.law.cornell.edu/regulations/california/22-CCR-97300