# Abbreviations

APCD: all payer claims database
APCD-CDL^™^: All Payer Claims Database Common Data Layout
APSE: Office of the Assistant Secretary for Planning and Evaluation
CDL: common data layout
CFR: Code of Federal Regulations
CMS: Centers for Medicare & Medicaid Services
COB/TPL: coordination of benefits and third-party liability
COVID: coronavirus disease
COVID-19: coronavirus disease 2019
DMP SAQ: Data Management Plan Self-Attestation Questionnaire
ED: emergency department
ERISA: Employee Retirement Income Security Act
ESI: employer-sponsored insurance
FEHB: Federal Employees Health Benefits
FFS: fee-for-service
FIPS: Federal Information Processing Standards
HCUP: Healthcare Cost and Utilization Project
HDHP: high-deductible health plan
HHS: U.S. Department of Health and Human Services
HIF: health information exchange
HIPAA: Health Insurance Portability and Accountability Act
ICD-10: International Classification of Diseases, Tenth Revision
IHS: Indian Health Service
IRB: institutional review board
LIS: Low-Income Subsidy
MEPS-HC: Medical Expenditure Panel Survey—Household Component
NDC: National Drug Code
OOP: out-of-pocket
OS-PCORTF: Office of the Secretary Patient-Centered Outcomes Research Trust Fund
PBM: pharmacy benefit manager
PCOR: patient-centered outcomes research
PHI: protected health information
PI: primary investigator
ResDAC: Research Data Assistance Center
SSN: Social Security number
SUD: substance use disorder
VHA: Veterans Health Administration