# Chapter 4 Summarizing Issues and Possible Actions

This report was produced to identify challenges and strategies for using APCDs for patient-centered outcomes research and multi-state use cases. To address these goals, we held semistructured discussions with leaders from state APCDs, data vendors that provide services to state APCDs, and researchers. Although stakeholders indicated that APCDs have the potential to be used for patient-centered outcomes research, they also noted missing data and missing populations as important limitations. Data linkages between APCDs and other administrative data were identified as an opportunity to address some of these limitations and examine research questions that cannot be addressed using data from APCDs alone.

Regarding multi-state analyses using APCDs, stakeholders saw significant potential benefits, including providing control groups to evaluate state policies and a sufficiently large sample to examine population subgroups and rare conditions. However, stakeholders mentioned barriers to using APCD data from multiple states, including differences across state APCDs in data release procedures and allowed uses, variation across states in file layout and data structures, and differences in intake and data processing procedures that could limit comparability even between states that receive similar files from payers and store data in similar layouts. Multi-state analyses have been successfully conducted, and some are currently underway, but some researchers also noted that the complexity and expense of a multi-state analysis might deter them from pursuing such work in the future, especially given uncertainty about the comparability of data across states.

## Issues and Possible Actions

Stakeholders identified a number of issues, which, if addressed, would help facilitate the expanded use of APCDs for patient-centered outcomes research and multi-state analyses. These issues and possible actions suggested by stakeholders are summarized in Table 4.1.

Table 4.1 Stakeholder-Suggested Options to Facilitate Patient-Centered Outcomes Research and Multi-State Analyses Using APCDs

Issues | Possible Actions (Implementer)
Missing race and ethnicity data in APCDs | - Link APCDs and hospital admission records, vital records, or other public health data (states)^a^; - Probabilistically impute this information in APCDs (states)^a^
Confusion related to 42 CFR Part 2 and the sharing of SUD data | - Clarify and improve communication to payers (federal government or states)^a^
Missing populations: Access to ERISA plan data | - Offer more outreach to ERISA plans, with customized reporting and benchmarks to encourage voluntary data submission (states)^a^; - Create legislation or regulation to require ERISA submission to state APCDs (federal government)^a^; - Collect ERISA plan data in a nationwide, federally supported database, which could then be shared with states and researchers (federal government)^c^
Missing populations: Access to federal health plan and health system data | - Create a dataset with these data that could be shared with states and researchers (federal government)^c^
Missing populations: Lack of data on the uninsured | - Link APCDs with hospital records, electronic health records, and other datasets to capture information on patients without continuous insurance coverage or those who self-pay for some care (states)^a^
Missing populations: Timely access to Medicare data | - Establish more-regular Medicare data submission to APCDs, potentially including using the APCD-CDL^™^ as a format for regular submission of Medicare data to state APCDs (states working with federal government)^b^
Uncertainty regarding what is included in APCD data across states and how these data can be used | - Gather and centrally disseminate current information about what populations and data are included in each state’s APCD and what uses are allowed (states)^a^; - Define metrics for APCD data completeness and support state reporting of these metrics (federal government working with states)^a^
Barriers to pursuing multi-state APCD collaborations and research | - Refine and share a draft common data application (federal government)^a^; - Produce and maintain a mapping between state APCD data layouts and the APCD-CDL^™^ (federal government)^a^; - Develop open-source software for APCD data intake and processing to help make data more comparable across states (federal government)^a^; - Create a learning network for users of multiple states’ APCD data (federal government or states)^a^; - Expand federal funding opportunities to encourage multi-state APCD work (federal government)^a^; - Expand federal funding opportunities to encourage linking of APCDs to other data to conduct PCOR studies (federal government)^a^; - Incentivize states to harmonize APCD datasets and data layouts, either with financial support or as a requirement to access federal health plan data (federal government)^b^
Lack of national or multi-state APCD | - Encourage states to submit their own APCD data to a federal data provider for purposes of building a multi-state resource (federal government)^c^

NOTE: The table lists issues identified by stakeholders and their suggestions of possible actions to address those issues. When possible, a party that might take a given action is identified in parentheses.

a These actions do not require data collection or data-sharing from the federal government.

b These actions potentially require data collection or data-sharing from the federal government but do not involve submission of state APCD data to a federally supported multi-state database.

c These actions involve establishment of a federally supported multi-state database.

### Missing Race and Ethnicity Data in APCDs

Stakeholders suggested strategies that states could take to address missing data on race and ethnicity and other information relevant to analyses of health equity. Addressing missing race and ethnicity data in APCDs aligns with Goal #4 in the OS-PCORTF Strategic Plan, Person-Centeredness, Inclusion, and Equity (ASPE, 2022). One suggestion raised by a participating state and by data vendors is that data linkages between APCDs and hospital admission records, vital records, or other public health data can help to fill in missing information in APCDs on demographic and socioeconomic status measures. Another approach, which is feasible in states that collect name and street address, is indirect estimation, in which these direct identifiers are used to probabilistically impute demographics to individuals appearing in the APCD. This type of approach has been used to address missing and incorrect race and ethnicity information for individuals with marketplace insurance plans (Sorbero et al., 2022), Medicaid (Silva, Trivedi, and Gutman, 2019), and Medicare (Haas et al., 2019) and was mentioned by one participating state as an approach they are actively exploring for use with data from their HIE.

### Potential Confusion Related to 42 CFR Part 2 and the Sharing of SUD Data

Two state participants noted continued challenges with the completeness of behavioral health and SUD data in APCDs. These state participants highlighted that payers have adopted widely varying practices for redacting these claims, attributing this variation to a perceived lack of current guidance from HHS about what claims can be shared. One state also remarked that some health care providers were uncertain about what information they could report on SUD patients, further undermining the accuracy of data submitted by payers. Although the Substance Abuse and Mental Health Services Administration has taken steps to encourage the inclusion of these data in claims databases—including the November 2022 notice of proposed rulemaking implementing changes required under the Coronavirus Aid, Relief, and Economic Security Act (Office of the Secretary, Department of Health and Human Services, 2022)—differing interpretations of 42 CFR Part 2 continue to limit the value of APCDs for studying behavioral health disorders and SUDs. These state participants suggested that HHS clarifications and communications around policies related to behavioral health and SUD claims could help address these challenges, along with outreach and education focused on payers or states with APCDs, who could then communicate this to payers.

### Missing Populations

Participating states and other stakeholders suggested a range of possible actions that could help to address the lack of data from ERISA plans, federal health plans, and federal health systems in APCDs.

#### Access to ERISA Plan Data

One approach that was described by a state participant and a vendor as successful at encouraging voluntary ERISA plan reporting was for the states to conduct targeted outreach and offer customized reporting and benchmarks to ERISA plans. This approach could be pursued by individual states but faces inherent limitations: Voluntarily submitted data from ERISA plans will still represent a convenience sample, and any inferences based on analyses with these data would rely on strong (and likely untestable) assumptions.

Overall, stakeholders noted that state efforts to collect ERISA plan data are inherently limited in their effectiveness under existing federal regulation due to ERISA preemption and suggested several federal actions that could better assist states in obtaining usable ERISA plan data. Multiple state participants said that federal action was necessary to address the challenges posed by ERISA plan nonparticipation in APCDs. One approach suggested by a state participant and a vendor was for the federal government to take regulatory or legislative action to require ERISA plans to participate in state APCDs. Another approach suggested by a state participant and a vendor was to have the federal government mandate the collection of nationwide ERISA plan data in a new national database. These stakeholders indicated that these data could then be shared with state APCDs.

#### Access to Federal Health Plan and Health System Data

Stakeholders also mentioned challenges related to missing data or untimely data submissions from federal health care payers. Participants from states with a large number of federal employees strongly emphasized the importance of obtaining data from the FEHB program. States also mentioned challenges that were due to missing data from TRICARE, the VHA, and IHS and expressed strong interest in obtaining data on enrollment and utilization for each of these programs. A state participant and a data vendor called for the federal government to address these issues by constructing a data resource that includes data from some or all of the above federal health plans and health systems, from which data on currently missing populations could then be distributed to state APCDs.

#### Lack of Data on the Uninsured

Stakeholders acknowledged how the lack of data on the uninsured in APCDs limited their value for studying populations who are persistently or even occasionally uninsured. A state participant mentioned that this limitation can be addressed in some cases through linkage of APCD data to hospital records, electronic health records, and other datasets, which can capture information on patients without continuous insurance coverage or those who self-pay for some care.

#### Timely Access to Medicare Data

While many state APCDs already include Medicare data, a data vendor and a participating state voiced concern about the data lags involved in Medicare data submissions to the states. This data vendor also noted the potential for error introduced by the need for CMS to submit data to states with varying submission formats. As an option to address these issues related to Medicare data, this data vendor suggested that the federal government could provide more-regular submissions of Medicare data to state APCDs using the APCD-CDL^™^ rather than tailoring the data submission to each state’s data layout.

### Uncertainty Regarding What Is Included in APCD Data Across States and How These Data Can Be Used

Researchers and participating states also highlighted a need for more information on the similarities and differences of APCDs across states:

- How can fields in each state’s data layout be mapped to a common format for use in analysis, and how do data definitions differ across states?
- What percentage of the state population is included in the APCD, and how complete are data submissions on each included population segment?
- Which payers and populations are included or excluded in each state?
- What uses are allowed with each state’s data?

Participants indicated that improving the collection of rigorous and comparable information to address these and other questions would be valuable to data users and would facilitate both single-state and multi-state research with APCDs. Researchers noted that better information about the populations included in each APCD and allowed uses would reduce barriers to initiating projects using multi-state APCDs. We note that some of this information is available on the APCD Council’s website, including, for each state, links to claims data collection rules, data release rules, and the data request process (APCD Council, undated-a). To enhance the visibility and usability of this information for researchers, states might consider summarizing this information and sharing it in a centralized location.

Alternatively, one vendor suggested that the federal government could support efforts at making information about what populations are included in APCDs by providing states with clearly defined specifications for a set of metrics reflecting APCD data completeness. This vendor suggested that such metrics might be reported in a similar format by the states and that the federal government might provide funding for states to establish comparable reporting on data completeness.

### Barriers to Pursuing Multi-State APCD Collaborations and Research

Several barriers to multi-state APCD collaborations and research were identified by stakeholders, and a number of possible actions were suggested to address these barriers.

To reduce researcher burden associated with filling out multiple different applications to obtain APCD data from several states and encourage greater use of multiple APCDs, researchers voiced support for the states adopting a common data application. The draft common data application included in Appendix D can be used as a model.

However, state participants indicated that the comparability of APCD content, differences in the data release processes, and differences in the types of files available for independent data users were challenges that would still need to be addressed to meaningfully reduce this burden, and that the effort involved in completing separate state applications was not the most significant barrier to multi-state analyses. One challenge mentioned by state participants and vendors is that substantial effort is needed to understand how states’ data layouts compare to one another. One suggestion made by a state participant was that a publicly available and regularly maintained mapping of states’ data layouts to the APCD-CDL^™^, which might be carried out or supported by the federal government, would facilitate multi-state use cases and the development of a multi-state APCD.

A similar concern raised by multiple vendors was that even states with identical data layouts may not have truly comparable data due to differences in data submission quality checks, thresholds for acceptance of submissions, business rules for data processing, episode groupers, or other technical differences in data intake and processing. One vendor suggested that the development and adoption of open-source software that could be used for data intake and processing would help ensure that information collected by different state APCDs was comparable.

Several state APCDs have established user groups that meet regularly for information-sharing between APCD staff, data vendors, and data users, such as independent researchers. Researchers suggested that the creation of a similar learning network or user group focused on multi-state APCD analyses could provide a forum for sharing lessons about multi-state analyses. An example of a similar network is the Medicaid Data Learning Network, managed by AcademyHealth with support from the Commonwealth Fund and the Robert Wood Johnson Foundation, which provides a forum for researchers to share their experiences and best practices for working with new Medicaid data (AcademyHealth, 2023).

Another barrier to multi-state APCD research identified by state participants and researchers is funding. Researchers observed that, at present, funders may view multi-state APCD research as high risk (i.e., unacceptably likely to fail), albeit with the potential for high reward. One researcher suggested that the federal government and other research funders (such as foundations) might help to promote multi-state APCD research by issuing requests for applications or other targeted calls for proposals specifically for projects that use multi-state APCD data. Such research funding or grants to states could also help promote linkages of APCD data to other datasets. One current example of this is the Robert Wood Johnson Foundation’s Health Data for Action (Data Access Award), which provides access to certain datasets for no charge—including APCD data from two states (Robert Wood Johnson Foundation, 2023). Similarly, state participants indicated that making resources available to expand and harmonize state-level data linkage efforts could allow for important multi-state use cases involving linked data.

State participants and vendors suggested that the federal government could also facilitate multi-state APCD use cases by taking steps to incentivize the collection of more comparable data in different state APCDs. While financial support could be offered to create such incentives, state participants and vendors noted that the creation of a national database containing data on populations missing from state APCDs could also be leveraged to incentivize standardization of state APCD data. If the federal government could collect federal and ERISA claims data from missing populations, state participants and data vendors suggested that state APCDs would have considerable interest in accessing these data. The federal government could then incentivize standardization of technical specifications across states where such variation hampers multi-state use cases. Specifically, data vendors suggested that the state receipt of federal payer and health system data could be conditioned on

1. standardization of data submission formats where these overlap with the APCD-CDL^™^ (without limiting the ability of states to continue using their own state-specific fields in addition to APCD-CDL^™^ fields)
2. standardization of data quality checks and thresholds for data submission acceptance
3. standardization of intake processes or business rules for processing data.

### Lack of National or Multi-State APCD

Researchers also voiced interest in obtaining multi-state APCD data from a national or multi-state APCD data resource. One model discussed by a state participant might resemble HCUP, in that states might be encouraged to submit their own APCD data to a national database, which might then disseminate multi-state data (including missing populations from ERISA and federal health plans and federal health systems). To construct such a federal claims database, states would need to be encouraged to submit their own APCD data to the federal data provider for purposes of building a multi-state resource. A more detailed proposal along these lines was laid out in McAvey (2022).

Some researchers did question the value of APCDs for multi-state use cases, noting that, at present, existing commercially owned databases offered a more usable resource for comparing commercially insured individuals across states than individual state APCDs. A researcher noted that these commercial databases often include Medicare and Medicaid populations covered through managed care arrangements. However, these existing datasets are often unaffordable for researchers at institutions with fewer resources, and the voluntary nature of these databases means that the continued participation of payers (or their continued availability to researchers) is subject to uncertainty. Creating a lower-cost alternative option could enable more-equitable access to multi-state claims data and enable patient-centered outcomes research on questions that might be challenging to address with existing claims databases.

## Conclusions and Next Steps

APCDs can be used to conduct patient-centered outcomes research that addresses a range of questions important to patients, caregivers, clinicians, and policymakers. The use of data from multiple state APCDs may further facilitate these studies by providing control groups to evaluate state policies and allowing the examination of population subgroups and rare conditions. Though current challenges related to missing data, missing populations, and differing APCD data limit broad multi-state uses of APCDs, stakeholders have identified a number of opportunities to address these challenges at the state and federal levels.