# Chapter 3 Multi-State Uses of APCDs

In this chapter, we summarize findings from our discussions with leaders from state APCDs, data vendors that provide services to state APCDs, and researchers related to the use of APCDs from more than one state, including potential and realized use cases, challenges, and strategies to encourage use of APCDs.

## Stakeholder Perspectives on Uses of APCDs for Multi-State Research

We asked stakeholders to share their perspectives about potential and realized uses of APCDs for multi-state research. Stakeholders from all groups mentioned that they had used APCD data from one or more states for benchmarking, including comparing the share of total medical payments spent on primary care, pediatric quality of care, and hospital prices across states. Researchers also mentioned using multi-state APCD data to study transitions in insurance coverage, cancer care, and vaccination and to compare quality of care among physicians affiliated and not affiliated with health systems.

Stakeholders also mentioned many promising use cases of interest using APCD data from multiple states. State participants mentioned a continued interest in using multi-state APCD data for benchmarking—specifically, being able to know how their state compares on prices, spending, or quality to both nationwide averages and neighboring states. Specific examples mentioned were comparisons of per member per month costs of primary care and behavioral health between neighboring states and rates of post-acute care utilization.

Examining policy changes using multi-state APCD data was mentioned as a promising use case by researchers and state participants. All types of stakeholders expressed an interest in examining balance billing and in-network and out-of-network spending across multiple states following the No Surprises Act (passed in 2020 as part of the Consolidated Appropriations Act of 2021, with out-of-network balance billing provisions effective in 2022), a potential multi-state APCD use case focused on economic impacts. Trends in pharmacy utilization and prices due to different policies were also mentioned as multi-state use cases of interest across all stakeholder types. Multi-state APCD data were mentioned by researchers as particularly important for providing a control group to examine the impact of statewide policy changes.

State participants also mentioned the value of using APCD data from multiple states to better capture and understand state border-crossing for health care. Combining data from multiple states’ APCDs was mentioned as a potential way to understand patterns of care-seeking across state borders and for learning more about facilities in neighboring states—for example, to analyze network adequacy or to include out-of-state providers in consumer-facing price comparison tools. A multi-state dataset could help illuminate where there are gaps or where each state is strong in a particular specialty—or whether providers in a particular state are delivering more low-value care than providers in other states.

Multi-state APCD data are particularly useful for analyses that are difficult to do with only single-state data. Researchers and state participants identified pooling data from multiple APCDs as a strategy to allow examination of small populations and rare conditions. For example, one state participant suggested pooling data across states and examining the per member per month cost of leukemia and other blood disorders.

### Example Use Cases

Building on insights shared from stakeholders, we developed two use cases that could be used by APCD staff or external researchers as a starting point for multi-state analyses:

- OOP spending for insulin users (Appendix B). State APCD data offer several advantages for studying insulin OOP spending. Inclusion of multiple payers and coverage types from both public and private insurance sources enables comparison of OOP spending across coverage types. Having medical and pharmacy claims for the same individual facilitates more-complete measurement of OOP costs and total costs of care. These data may support state-specific estimates, which are not generally feasible with other health care datasets. Finally, APCD data are often available sooner than other datasets (e.g., household survey or commercial claims datasets), though the time lags relative to other datasets vary widely across states.
- Costs for individuals with long COVID-19 (Appendix C). Many APCDs can capture individuals as they churn across different types of insurance over time, which enables a lengthy period of follow-up post-diagnosis. Furthermore, in states with a linkage to an HIE or state laboratory testing data, it might be possible to identify total costs of long COVID dating back to the initial positive COVID-19 lab test result.

The example use cases identify specific data files and data elements to be used and are based on the All Payer Claims Database Common Data Layout (APCD-CDL^™^) from the APCD Council, the National Association of Health Data Organizations, and the University of New Hampshire (APCD Council, National Association of Health Data Organizations, and the University of New Hampshire, 2021). Not all states use the APCD-CDL^™^, however, and states and vendors noted that it could require substantial effort to map data elements from different states to the APCD-CDL^™^. One state participant suggested that multi-state research could be facilitated by an effort to map state data elements to the APCD-CDL^™^ to highlight direct matches and state-specific variations. This could reduce barriers to the development of multi-state use cases and help to ensure that results from use cases such as these are comparable across states.

Although these use cases do not provide sufficient detail to support immediate implementation, they are intended to provide examples of how APCDs can be used for patient-centered outcomes research and how a multi-state approach might further enhance the value of APCD data. For example, pooling data across multiple states may allow for the exploration of economic outcomes, including among diverse patient populations (consistent with Goal #4 in the OS-PCORTF Strategic Plan [ASPE, 2022]). Using data from multiple states could allow for the examination of the impact of different state policies, such as state policies related to drug price transparency or state-level reforms that have capped OOP insulin prices. That said, analyses using more than one state APCD should be approached with care, because they require understanding the similarities and differences of APCDs across states, including obtaining data, allowed uses of data, and the populations included (e.g., varying shares of ERISA plan reporting).

## Challenges and Strategies

Despite high interest in using APCD data from multiple states, stakeholders identified challenges, which we describe below, along with their suggestions for addressing them.

### Variation in Processes for Obtaining Data

Researchers using data from more than one state APCD indicated that having to obtain data separately from each state was often a confusing and time-consuming process. One researcher stated that "the process for obtaining data can vary from state to state and even vary year to year within a state." Another researcher noted that they experienced "huge variation in obtaining data from states, in helpfulness, timeliness, cost, and what data was available."

Researchers indicated that the information requested in data applications was reasonable, but it was tedious to fill out multiple similar applications. Some states had additional processes for researchers to obtain Medicaid data and additional questions about external data linkages. We heard from one stakeholder who participated in a multi-state APCD analysis that there were challenges throughout their project, including obtaining permission to directly analyze each state’s data and to utilize comparable data elements across all participating states. States also had different timelines for data release, which researchers indicated made it challenging to obtain data for the same years from multiple states at the same time. The cost of purchasing APCD data was also mentioned as a barrier to multi-state APCD research by some researchers. However, one researcher noted that the state that charged them the most for an APCD was the most responsive to their questions, which they indicated was extremely helpful, suggesting that these higher costs may be supporting staff time to interact with data purchasers.

Another barrier mentioned by multiple state participants was the occasional inaccessibility and extra restrictions associated with public insurance data in comparison to the commercial claims data in the APCD. Specifically, the approval and release processes for Medicaid and Medicare data could be challenging and costly, leading to inconsistency in the breadth of data contained in different states’ APCDs.

#### Common Data Application

We specifically asked stakeholders if a common data application—that is, a single data request form that could be submitted by external researchers to request data from multiple states simultaneously—might facilitate research using APCD data from multiple states. Stakeholders generally agreed that this would facilitate multi-state use of APCDs. Participants from two states suggested that the common data application could include the common fields across all the APCDs as mandatory fields while leaving the more expansive data collected by some states but not others as separate, optional fields or state-specific add-ons.

We heard from both state participants and researchers that a common data application is a good idea in theory but that it would be difficult to implement until all APCDs had a common data layout (CDL) with harmonized variables. Variation in data request processes was also mentioned as a potential barrier to a common data application. One state cautioned that state review committees would likely be sensitive to being overstepped and will still want to have a say in what gets released via a common data application.

After reviewing elements that appear in six existing state APCD data applications, the HCUP data application, and ResDAC’s data application and holding conversations with key stakeholders, we developed a prototype common data application (Appendix D) and an annotated common data application (Appendix E). The annotated application includes text describing why certain elements are included and deviations observed across applications, and it highlights outstanding issues—such as the challenge of using a common data application when datasets are not standardized across states. Some instances of variation are highlighted below:

- Study aims: While all applications asked applicants to describe their study aims, the level of detail requested varied. This could be a brief 150-word abstract or may include a more extensive explanation of project objectives, a brief summary of the literature, specific research question(s), individual specific aims, project methodology, and a description of intended products or reports to be derived from the requested data.
- Purpose: Applicants were typically instructed to check a box to indicate the purpose of the project. This item could be used to distinguish between research, health care operations, or public health activities. There was variation in the level of detail provided, with some applications including potential purposes for the data request: for example, assess utilization of health care services, observe cost trends, compare providers/health plans, create or enhance a commercial product or service, or assess population health.
- Data linkages: About half of the applications reviewed asked about data linkages. One state strongly prefers to conduct any data linkages in house prior rather than providing the dataset in order to prevent potential reidentification by linkage.
- Standard limited dataset: Sometimes a standard limited dataset was available, and requesting this may allow applicants to complete a shorter application. When a standard limited dataset was not available, the application typically included many questions to determine the least amount of data that can be shared to achieve the project aims.
- Data security: The amount of information about data security requested by state APCDs varied widely. Some applications had more requirements related to data security, and some had less.

### Variation in Allowed Uses for Data

Some states have legislative restrictions regarding the uses for which their APCD data can be released. For example, despite high interest in public health surveillance, some APCD data can only be released for official statistical or research purposes, not public health surveillance. Some APCDs do not allow for the identification of prices for individual providers, and others are not available to external researchers. Additionally, the inability or unwillingness of some states to pool data with other states was noted as a barrier to multi-state research—this was not described as a major barrier, as researchers and data vendors indicated that there are times when pooling data would not be appropriate (e.g., when examining states that greatly differ in geographic location and population characteristics), and there are strategies for dealing with this (e.g., aggregating data and then pooling them or having states run analyses themselves and then sharing results). Reasons provided by researchers for separately analyzing data from multiple states rather than pooling data included data use agreements prohibiting the pooling of data, different security requirements across state APCDs, the large size of datasets, availability of different years of data, and different timelines for receiving data. Overall, researchers indicated that it was often unclear what APCDs allowed or did not allow researchers to do with these data, and researchers requested more transparency from states about these restrictions.

State participants indicated that states had different norms for sharing data extracts with researchers—something that researchers and state participants indicated would present a challenge to using a common data application across states. Some states have a standard limited dataset that can be released and tailored to include more or less information (e.g., full dates versus month and year only), while other states produce custom datasets for each request. Two state participants indicated that they tailor extracts based on what is requested to ensure that they release only the minimum necessary data to complete the requester’s project, though one of these states is considering creating more streamlined limited extracts that could be requested and provided without tailoring. One state participant noted that they expected that state-to-state differences in output files would matter more than any differences in data request processes or layout.

### Variation in File Layouts, Data Structure, and Data Cleaning

As highlighted in Goal #2 of HHS’s Strategic Plan for the OS-PCORTF (ASPE, 2022), data standards and common data models facilitate data sharing and use. Stakeholders had different perspectives about how much of a barrier the different layouts of APCDs were to multi-state APCD research. One researcher who indicated that this was not much of a barrier stated that the files were "pretty similar" across states and that, while these files were "messy," that was similar to their experience with other claims datasets. Another researcher indicated that these differences were a large barrier to multi-state APCD research, saying:

I don’t know that I would want to combine state APCDs. I don’t know how that would be feasible because it’s not standardized at all, it’s worse than how Medicaid data is not standardized state to state.

The APCD-CDL^™^ from the APCD Council is a potentially important tool for states to use to produce comparable APCD data (APCD Council, National Association of Health Data Organizations, and the University of New Hampshire, 2021), but barriers to adoption of the APCD-CDL^™^ were noted. One vendor noted that states who created APCDs before the development of the APCD-CDL^™^ may not have an interest in (or the funding to support) the investment needed to adopt the APCD-CDL^™^. This vendor noted that the transition costs associated with changing their process could be significant relative to existing APCD budgets.

A vendor also noted that, although there had been hope that the APCD-CDL^™^ would be adopted for voluntary submission by ERISA plans (as recommended in 2021 by the Department of Labor’s State All Payer Claims Databases Advisory Committee [State All Payer Claims Databases Advisory Committee, 2021]), this has not happened. State participants generally supported using the APCD-CDL^™^, with the caveat that some states collect more information than is supported by it. One state participant, for example, mentioned that their APCD collects more information on primary care and behavioral health than other states do, and another state participant asserted that adopting the APCD-CDL^™^ would result in a loss of important information about race and ethnicity compared to the state’s current data layout.

However, differences between current state data layouts and the APCD-CDL^™^ were framed as not insurmountable, as long as there is sufficient standardization to support useful comparisons. One state participant mentioned that they had recently changed their data submitter guide to align more closely with the APCD-CDL^™^ and noted that being more aligned with those standards would make it easier to participate in multi-state aggregation efforts. Another state participant said that a CDL would do the most to foster data use across states by producing directly comparable datasets.

Multiple vendors noted, however, that use of the APCD-CDL^™^ alone was insufficient to address differences across states that affect the validity of findings from multi-state analyses. First, one vendor raised the concern that, if the APCD-CDL^™^ were adopted as a format for data storage to enable the creation of more comparable analytic files for multi-state analyses, states that use different or more detailed data layouts for submission from payers might lose information when data are formatted to match the APCD-CDL^™^:

The goal of CDL was if you store data in that format, it’s better in a theoretical cross-state share; but if the APCD is storing all their data in the CDL [i.e., if they only keep the analytic file], then fidelity is lost.

Second, even the adoption of the APCD-CDL^™^ does not eliminate the possibility that heterogeneity in intake processes or other business rules will reduce the comparability of data across states: Even states that use the APCD-CDL^™^ might have challenges with comparability due to other steps in the data pipeline that are not specified in the APCD-CDL^™^. Multiple vendors voiced the concern that differences in data intake across state APCDs—especially across states that work with different vendors for data management—could make it substantially more difficult to make valid comparisons across states. The application of alternative diagnostic groupers or other proprietary algorithms for processing claims data (e.g., identifying inpatient versus outpatient hospital episodes) was identified as an example in which steps taken relatively early in the data processing pipeline can limit comparability across state APCDs in ways that are difficult or impossible to reverse. One vendor said:

All data aggregators do it all differently, it can be like taking a copy of a copy of a copy.... [It is] easier to go across payers than to go across states because you don’t know how data aggregators are standardizing to manipulate the data in their state.

A vendor also noted similar comparability challenges with consumer-facing price transparency tools in neighboring states: The methodologies were different, so prices reported by the two states’ tools were not comparable.

One vendor felt strongly that the critical point in the data-processing pipeline for standardization across states was at the very beginning. This vendor suggested that the development and adoption of open-source algorithms and standards for intake of claims data would be a good path to address this problem. If reliable open-source software were available, then states could specify that a vendor use software that promotes standardization of the data intake process. While another vendor that works with multiple states felt that they already had good transparency about how data were handled, they indicated that there was room for greater standardization across states in other areas, such as how claims versioning was done.

In a similar vein, a different vendor called for the establishment of

a place to share methodology for more prickly areas and to understand how data are being processed; it could be GitHub or something else for information to be shared on how analysts or data managers have constructed data variables, so that they could be used differently.

Furthermore, one vendor noted that data submission to state APCDs by CMS had longer lags than were tolerated for other payers and that the state-by-state process through which CMS provides data to state APCDs led to issues with comparability, noting:

Every state receives Medicare data and has a unique mapping into a more standard APCD format, but that creates a new opportunity for misalignment.

### Variation in Missing Data and Missing Populations

One vendor noted that missing populations in state APCDs are a greater threat to internal validity for cross-state comparisons than for single-state analyses because "issues get hidden." They noted that, due to ERISA, VHA, and other missing populations, the completeness and reliability of data for one state’s price comparison tool varied widely across hospitals within the state; that vendor pointed out that these issues are even harder to track accurately and address if data are combined for multi-state comparisons. A vendor also noted that vendors are not in a good position to initiate efforts to improve data submission (for example, by encouraging voluntary submission by ERISA plans) unless state APCD leadership is interested. On this topic, one vendor said, "We are fully dependent on the state to take it as far as they want."

As noted in Chapter 2, researchers also identified variation across states in missing populations as a barrier to working with multiple state APCDs. Differences across states in the size and composition of missing populations are compounded by the scarcity of information about which populations are included in each APCD. One researcher summed this up by saying,

I wish it were a little easier to know who’s included and who is not included in the APCD. It’s not always consistent across the states.

Researchers mentioned that it would be helpful if more states shared information about what proportion of (or if any) ERISA plans in a state submitted to the APCD and if the APCD includes information only on state residents seeking care in that state or anyone seeking care in that state.

One vendor echoed this criticism, saying that information about the completeness of data in an APCD they operate was not transparent; this vendor suggested that some state governments may lack the technical sophistication or resources to rigorously compare how the population in the APCD compares to a population of interest (e.g., the population of state residents with health insurance or the population with ESI coverage). This vendor also indicated that, even when a state understands the completeness of its APCD data, this information was often not reported to the public in a transparent or readily available manner.

State participants and researchers also indicated that the lack of information about race and ethnicity was a challenge, albeit a challenge that was common to all states. One vendor, however, noted that some payers had concerns about sharing demographics such as race and ethnicity because they had not obtained consent from their policyholders to share that data for research.

Several strategies to reduce missing populations in APCDs were discussed. One state participant mentioned that a multi-state APCD could begin with a federally initiated database of currently missing data (for example, ERISA plans and FEHB program data), then add existing state APCD data, rather than attempting to harmonize existing but incomplete APCDs. It was also suggested that the federal government is better positioned than states to require participation from self-insured employers and could use specific use cases as an incentive for self-insured plans to submit data to a multi-state APCD. Another state participant mentioned that the ability to extract data from multiple states may encourage ERISA plans to submit data. Many of the self-insured employers in that state employ residents of surrounding states as well and, it was suggested, could learn from a multi-state regional APCD whether their benefits were competitive with other, similar employers.

In addition to mentioning the lack of mandatory submission by ERISA plans, one vendor suggested that state and federal policymakers are able to signal to players in the health care industry (both payers and facilities/providers) that transparency in prices is the government’s expectation in hopes of promoting a culture shift that reduces barriers to data-sharing and APCD participation. Examples of such policies include funding for APCD operations and preemptively addressing arguments against sharing by payers (e.g., that the Health Insurance Portability and Accountability Act [HIPAA] prevents the sharing of claims data with APCDs or that the sharing of claims data represents a unique threat to members).

Vendors also mentioned that there is momentum toward greater data privacy, including allowing patients to opt out or censor certain parts of their records, fueled, in part, by concerns among some patients and providers about protecting reproductive health information from law enforcement.

### Funding and Future of APCDs for Research

Lack of funding was mentioned as a barrier to working with multiple APCDs by state participants and researchers. Less-populous states with fewer APCD staff face a particular challenge of having less funding and less bandwidth to pursue additional funding opportunities, despite having ideas and cohesive plans for multi-state efforts. One state participant reported that they submitted a federal grant to support a three-state effort to create a public-use multi-state dataset. However, the grant was not awarded, and the work was unable to move forward without funding. Some state participants indicated that they are exploring multi-state collaborations, which may include developing common research agreements, combining data, or harmonizing outputs. However, lack of additional funding or federal support can make it difficult for states to prioritize these multi-state efforts.

Some vendors handle data processing for multiple states’ APCDs, and one state participant suggested that federal monetary support could encourage such vendors to pursue harmonization efforts and facilitate multi-state comparisons. One vendor suggested that federal support for states to adopt the APCD-CDL^™^ would be valued because states with APCDs that predate the APCD-CDL^™^ may otherwise lack the resources needed to overhaul their data intake procedures and documentation.

One researcher cautioned that research proposals using APCDs may be viewed as "high risk, high reward" because of the uncertainty around what is included in APCDs and how they can and cannot be used. This researcher suggested that a grant call be issued for research using APCDs to offset data costs and encourage innovative uses of multi-state APCDs, including linkages to other datasets. This echoes what we heard from one state participant, which was that while researchers may want to access data from multiple states’ APCDs in order to produce more generalizable findings, it is mainly large and well-funded research organizations or universities that are able to navigate the multiple different data request processes for each APCD.

Researchers were divided on whether they planned to continue to work with data from multiple APCDs. Some researchers viewed APCD data as much cleaner and easier to obtain than data acquired directly from private insurers. However, one researcher was not sure that the complexity of working with APCDs was worth it compared to using other data sources, such as private claims data or HCUP discharge data. Reflecting on navigating multiple application processes and trying to understand data from multiple states, another researcher lamented:

I worry that APCDs will go to the wayside because private companies are doing a good job pulling data together at a large scale. The cost is a lot more, but there are more people and more states. There’s only one vendor, it’s a more streamlined process. They want you to be a happy customer.