# Chapter 2 Use of APCDs for Patient-Centered Outcomes Research

In this chapter, we summarize findings from discussions with leaders from state APCDs, discussions with data vendors that provide services to state APCDs, and discussions with researchers related to building and strengthening data capacity for using APCDs for patient-centered outcomes research. Potential and realized use cases using APCDs, as well as challenges and opportunities related to facilitating use of APCDs for PCOR studies, including missing data, missing populations, and linkages, are discussed in the context of the four goals of the OS-PCORTF Strategic Plan (ASPE, 2022), as presented in Chapter 1.

## Stakeholder Perspectives on Uses of APCDs for Patient-Centered Outcomes Research

During discussions, we asked stakeholders to share their perspectives about potential and realized uses of APCDs for patient-centered outcomes research. As related to Goals #1 and #2 of the OS-PCORTF Strategic Plan, stakeholders noted that APCDs cover a range of health insurers, making them well-suited to study state and federal health programs and the populations served by them. Researchers also indicated that APCDs can be used to examine disparities of care between Medicaid and commercially insured patients and to study children’s health, because Medicaid is generally included in all APCDs and is a major payer of children’s health care.

Stakeholders emphasized the complexity of APCD data and highlighted the need to increase knowledge across a variety of users and potential users, consistent with Objective 1.4 of the OS-PCORTF Strategic Plan, which focuses on engaging end users throughout the process of building data capacity. One vendor stated that a limiting factor in analysis of existing APCD data is users’ familiarity with the data and the availability of people with expertise to work with complicated data. This vendor emphasized that:

Anything is possible if you try; it comes from real investment of human capital. You have to have smart people looking at it, making business decisions based on what the data tells you. We look at it, drop fields when not reliable, or fix it as possible.

Some stakeholders further emphasized the challenge of working with APCD data and the need to develop an in-depth understanding of APCD data. Researchers appreciated state APCDs that were responsive to their questions and allowed them to better understand particular datasets. One researcher suggested that a workgroup or consortium could be formed to allow the sharing or archiving of the experiences and lessons learned from previous researchers.

Aligned with Goal #4 (Objective 4.3) of the Strategic Plan, stakeholders mentioned that APCDs were uniquely valuable for examining economic outcomes (and generating evidence to inform patient decisions). For example, data vendors mentioned that APCDs provide an opportunity to compare prices and allow comparisons of service use and quality of care across payers or across providers. One researcher emphasized that a strong APCD infrastructure can help a state to implement policies that promote the health and well-being of its residents—noting that research using APCDs has been used to benchmark premiums for a public option health plan and to cap facility fees for hospital services. Multiple state participants and vendors emphasized that APCDs are an important resource for measuring the total cost of care for specific health conditions or populations, which can be relevant to understanding patient OOP costs.

## Challenges and Strategies

Although stakeholders recognized that APCDs were well suited to support research and analyses on a range of questions within patient-centered outcomes research, they noted a number of challenges and strategies for addressing them, which are described below.

### Missing Data

Researchers and state participants noted a common barrier to using APCDs for PCOR studies and examining health disparities: missing information about race and ethnicity, an issue affecting all administrative health care data. Addressing this missingness may help to achieve Goals #1 and #4 of the OS-PCORTF Strategic Plan. One state is exploring imputing missing information on race and ethnicity using patient surname and residential address. Another state participant discussed an equity initiative in their state that sought to encourage more accurate reporting of race and ethnicity in patient-level hospital encounter data; the state participant suggested that this effort might have positive impacts in reducing missing race and ethnicity data in their APCD (this initiative is in its early stages). One state participant mentioned, however, that even when this information was filled in, they had no way to know whether the information was self-reported by the patient or completed by a third party via observation, so there remained uncertainty about provenance and accuracy (which affects the quality of the data).

Related to Goal #1 of the OS-PCORTF Strategic Plan (ASPE, 2022), stakeholders mentioned that APCDs were a promising resource for studying substance use disorder (SUD). However, participants from multiple states also mentioned that data submitters continued to redact claims data related to SUD treatment and that ambiguity around 42 Code of Federal Regulations (CFR) Part 2, which provides federal requirements for the confidentiality of SUD patient records, was a barrier to data completeness. Although SUD records can be disclosed for research purposes and included in APCDs, some state participants mentioned variation in submitters’ interpretation of the statute as a challenge, noting that some payers conservatively withhold or omit even permissible data in an effort to ensure that they do not run afoul of regulations. One state participant provided an example of this, indicating that one data submitter might remove only SUD diagnosis codes from encounter records, whereas another data submitter might remove the entire patient encounter. This participant noted that these inconsistencies across payers in how data submitters understand 42 CFR Part 2 make it difficult to rely on the APCD for studying SUD treatment (for example, to measure what proportion of behavioral health spending is related to SUD).

### Missing Populations

All stakeholders mentioned the need to improve the representativeness of data, which aligns with the emphasis on equity and inclusion of data from all communities in Goal #4 of the OS-PCORTF Strategic Plan. Several states and researchers cited the lack of data from self-insured plans covered by the Employee Retirement Income Security Act (ERISA) as their largest missing population. With the end of the federal coronavirus disease 2019 (COVID-19) Public Health Emergency, which is expected to shift many patients from Medicaid to private insurance, the lack of data from self-insured plans is coming to the forefront. Without these data, participants from multiple states indicated that they can neither quantify what proportion of their population is employer-insured nor characterize their employer-sponsored insurance (ESI) market in terms of risk and utilization. Furthermore, the share of the market covered by ERISA plans varies state to state, and the share of ERISA plans missing (or not missing) from APCDs also varies by state. Researchers highlighted this variation as a challenge to working with multiple state APCDs, with one researcher saying:

There is a sense that you are always missing the same people across states, but the rates of [that missingness] vary a lot across states.

Researchers encouraged APCDs to share information about who is and is not included in each dataset when possible. Stakeholder perspectives on barriers posed by the unavailability of this information are discussed in Chapter 3 in the "Variation in Missing Data and Missing Populations” section.

States have pursued and continue to consider a variety of approaches to encourage voluntary submission of data from plans covered under ERISA. One state participant shared that they have found success by reducing the reporting burden for these plans and by being more lenient with the submission guide, working from the perspective that any data, even if incomplete or not comprehensive, are better than no data. This process involved a significant upfront effort coordinating with plan administrators for about a year. Asked why some ERISA plans opt into reporting, the state participant said:

We assume they see the value and importance of having this data available to researchers and our other approved stakeholders to improve health and identify gaps and hotspots.

Another state participant indicated that their potential interest in accepting incomplete data from ERISA plans depends on the intended uses of the data; for example, if the focus of research is utilization, detail on payments may not be necessary.

However, state participants also highlighted limitations of the current situation with ERISA plan data and noted that some time-consuming efforts to encourage voluntary submission had yielded very little in return. Another state participant mentioned that they instituted a pre-processing tool to deidentify all individual patient identifiers in an effort to ease plans’ concerns about data privacy and encourage data submission. This effort, however, did not gain traction among ERISA plans, and it created more work for the APCD on the back end. It also prevented the linkage of APCD data to other administrative data, such as death records. Another state participant argued that individually asking each self-insured plan to opt into reporting will never result in comprehensive data and instead suggested that federal legislation would be much more effective.

Other state participants, meanwhile, mentioned that their states are still thinking about how to encourage submission by ERISA plans. Participants from two states mentioned an interest in demonstrating to ERISA plans the value of an APCD by sharing output that these plans could use to inform benefit design or compare themselves to similar groups. A data vendor mentioned that this has been a successful strategy in one state where they operate.

Stakeholders also flagged other populations missing from APCDs. Researchers mentioned that the lack of information about the uninsured makes it challenging to study insurance churn using APCDs. State participants also mentioned lack of data from insurers, such as the Federal Employees Health Benefits (FEHB) program and TRICARE (the health care program for military service members, retirees, and family members) as challenges. States with a large share of federal employees mentioned the lack of data submitted by the FEHB program as a significant challenge. Some states also mentioned lack of data from health care systems, such as the Veterans Health Administration (VHA) and the Indian Health Service (IHS), as a challenge because of missing information about both enrollment and utilization of care in those health care systems. One state participant noted that they have a significant American Indian population but that services provided at IHS clinics and paid for with IHS funds are not shared with the APCD, thus resulting in data that are missing not at random (MNAR), which threatens the internal validity of research on this population (Little and Rubin, 2019). This state participant indicated that a multi-state analysis of health status and health care use for a tribe would be particularly interesting, because tribal organizations often cross state boundary lines, so understanding this population as a whole might require data from multiple state APCDs.

### Longitudinal Analyses

A strength of APCDs mentioned by state participants and researchers is the ability to follow individuals over time as they receive care in different settings and change health plans, which aligns with Goal #2 in the OS-PCORTF Strategic Plan: to expand longitudinal data resources for patient-centered outcomes research. Nearly all state participants indicated that their APCD supports longitudinal linkage, although one state participant noted that they could currently do this only for individuals with private health insurance. Researchers reported that it was very helpful that states made efforts to link individuals across plans, but one researcher noted that the validity of the linkage of an individual’s records from different insurers and over time was not always clear. This researcher’s comment was offered as part of a larger appeal for state APCDs to share more information with researchers about the strengths and limitations of their APCD data. Additionally, state participants indicated that they struggle with tracking individuals who may receive care across state lines, particularly in multi-state metropolitan areas, because states typically have enrollment and claims for state residents but lack out-of-state claims for nonresidents who utilize care in their state.

### Data Linkages

The five states participating in group discussions on the topic of data linked to APCDs had linked APCD data with a variety of different data sources, including disease registries, hospital discharge data, vital records, criminal justice data, social service data, and electronic health record data. State participants indicated that they sometimes linked datasets on a regular basis and other times linked data on an ad hoc basis in response to specific requests.

State participants described several different approaches to data linkage, which varied based on the specific datasets linked. These methods generally involved probabilistic matching on multiple different variables, such as name, date of birth, and address components. Some states could use Social Security number (SSN) or a deidentified equivalent in the matching process, which greatly increased the match rate and ease of matching. However, one state participant noted that, by state law, their agency could not collect SSNs and thus could not use this variable in their linkages. Many states either used or were developing common master patient identifiers that would allow matched data to be used internally without SSNs or other identifiers.

Participants cited a few key challenges in the technical processes of linking other data to APCDs. One state participant noted that sometimes Medicare Advantage plans and pharmacy benefit managers (PBMs) would submit data with a single member ID for an entire family, causing the claims data to link to multiple records in the other datasets. Another key challenge with linking PBM data noted by a participant was that PBMs sometimes submit data separately from insurers. If a research question requires linking both pharmacy claims and medical service claims to another source of data, this can generate multiple record numbers for the same person, complicating the linkage process. Another state participant noted a similar challenge, but they were able to address the issue by using an encrypted user ID from its health information exchange (HIE).

While all state participants acknowledged technical challenges, they noted that the larger challenges were often legal or organizational. Linking data proved difficult when not supported by statute or when trying to link across separate organizations within a state. Once the data were linked, end users of the data sometimes also faced challenges, including computational intensity. One state participant mentioned that because they regularly link many datasets to the APCD, the volume of data can be computationally difficult to handle.

Several state participants noted that their states were first motivated to begin linking APCD data based on a specific research question or use case important to the state. In one state, the initial investment in data linkage infrastructure was motivated by legislation to examine trends in opioid overdoses. This initial investment and demonstration of use cases helped to expand to linkages with additional data sources to address such topics as maternal and child health, COVID-19, and the impact of climate change on public health. In another state, a participant indicated that they first linked their APCD data with vital statistics data to facilitate a research study on end-of-life care and then used these linked data in additional studies. Another participant noted that a major motivation to begin linking APCD and hospital discharge data was to enhance race and ethnicity data that were frequently missing from the APCD.

Overall, discussion group participants saw great promise in using APCD data linked with other sources to answer important research questions. Participants from multiple states agreed that linking APCD data with other data sources was important for studies of health and health care inequities. In addition to pursuing person-level data linkages to improve race and ethnicity data, participants also noted the potential of geographic-level (e.g., county or census tract) data linkages to understand health care issues in rural or socially disadvantaged areas. Another participant noted that linked data could be useful to observe self-pay care among insured individuals (i.e., through linkage of APCD data with hospital discharge or electronic health records that capture self-pay service use).

While most state APCDs began by using linked data within the state government, they are increasingly sharing their data with external organizations, particularly state universities, allowing exploration of a broader set of research questions. Participants from multiple states noted many use cases for linked data within their state. While participants expressed interest in conducting multi-state studies using linked data, they noted that this was generally not feasible given that states have linked different datasets using different methods. State participants noted that making resources available to expand and harmonize linkage efforts could facilitate patient-centered outcomes research using multi-state data.