# Chapter 1 Introduction

All payer claims databases (APCDs) collect data on health insurance enrollment and claims across public and private insurance plans within a single state. Today, 25 states have a mandatory APCD currently operating or in implementation (APCD Council, undated-b). Creation of APCDs has been motivated by a wide variety of goals, including improving the health of the population, reducing or controlling the growth of costs, and promoting price transparency (McCarthy, 2020).

State APCDs have already been used to support a wide range of policymaking and operational activities in line with the objectives envisioned by state legislatures that established APCDs. Some examples include informing legislation on surprise billing and prescription drug prices, monitoring network adequacy, providing consumers with price transparency information, understanding population health, and evaluating the impacts of state policy and reforms (Carman et al., 2022).

State APCDs offer an opportunity to support patient-centered outcomes research (PCOR), which can be defined as follows:

Patient-centered outcomes research aims to generate high-quality evidence about the effectiveness of treatments, services, and other health care interventions on the full range of outcomes that patients, caregivers, clinicians, policymakers, and other stakeholders have identified as important. (Office of the Assistant Secretary for Planning and Evaluation [ASPE], 2022)

APCDs can provide data on health care utilization needed for PCOR studies.^1^ For example, APCDs have been used to study such patient outcomes as opioid overdoses (Burke et al., 2020), delivery of appropriate care (Haakenstad et al., 2019), and out-of-pocket (OOP) costs (Steenland et al., 2019). Moreover, the expanded use of APCDs can support the U.S. Department of Health and Human Services’ (HHS’s) efforts to achieve the goals set forth in the new Strategic Plan from the Office of the Secretary Patient-Centered Outcomes Research Trust Fund (OS-PCORTF) (ASPE, 2022):

1. Data Capacity for National Health Priorities: Build data capacity for patient-centered outcomes research that informs the needs of federal health programs, providers, and the people served by these programs.
2. Data Standards and Linkages for Longitudinal Research: Expand longitudinal data resources that enable patient-centered outcomes research to advance evidence generation.
3. Technology Solutions to Advance Research: Leverage leading technology solutions to improve data capacity for patient-centered outcomes and comparative clinical effectiveness research.
4. Person-Centeredness, Inclusion, and Equity: Expand the collection and analysis of socioeconomic, environmental, and other data so all people making health care decisions have the evidence they value about the outcomes and effectiveness of health care. (ASPE, 2022)

Many of the goals cited by states for establishing APCDs are connected to patient outcomes, such as improving population health and providing quality and price information to inform patients’ choice of providers.

However, limitations of existing state APCDs have been extensively documented. Readers interested in an overview should consult Miller et al. (2010) and Carman et al. (2022). These limitations include the payers and populations captured (or not captured) and the completeness of data elements that are submitted.

The state-by-state nature of the APCD landscape also means that research and analyses using APCD data often include only single-state data. While single state analyses are useful for many applications (and may be preferable for some applications because of differences in states’ health care systems and policy environments), there are also numerous use cases in which cross-state comparisons or multi-state analyses that pool data from multiple state APCDs could offer advantages. Key examples include research on statewide policy changes (which may require data from another state to provide a suitable comparison group) and research on population subgroups and rare conditions (which may require multi-state data to obtain a sufficiently large sample).

Addressing limitations of existing APCDs, which arise from a variety of sources, could increase the utility of APCDs for policymakers, researchers who focus on patient-centered outcomes and other topics, and public health. As noted in the OS-PCORTF strategic plan, further development of APCDs, including a database combining multiple existing state APCDs, could build and strengthen longitudinal data capacity by providing information on patients’ health care utilization and outcomes over time, across geographic boundaries, and across multiple care settings (ASPE, 2022).

## Objectives and Approach

This report was commissioned to identify challenges and strategies for using APCDs for patient-centered outcomes research and multi-state use cases—with a focus on missing data, missing populations, and data linkages. This was accomplished through several activities:

- a series of semistructured individual and group discussions with stakeholders
- preparation of a draft common data application that could potentially be used to request APCD data from multiple states
- creation of research plans for two use cases involving multiple state APCDs.

### Stakeholder Discussions

Individual and group discussions with stakeholders were held in the spring and summer of 2023. Table 1.1 summarizes the topics and number of participants by stakeholder group and discussion modality. This report describes findings from those discussions.

Table 1.1 Overview of Stakeholder Discussions and Major Topics

Topics Discussed | State Discussions | Vendor Discussions | Researcher Discussions | State Group Discussions
Use cases | Yes | Yes | Yes | No
PCOR studies | Yes | Yes | Yes | No
Multi-state analyses | Yes | Yes | Yes | No
Missing payers and populations in APCDs | Yes | Yes | Yes | No
Missing data in APCDs | Yes | Yes | Yes | No
Longitudinal data linkage | Yes | Yes | Yes | No
Value of common data application | Yes | Yes | Yes | No
Data linkages with non-APCD data | No | No | No | Yes
Sample Size | State Discussions | Vendor Discussions | Researcher Discussions | State Group Discussions
Number of participants | 6^a^ | 3^a^ | 4 | 5^a^

NOTE: “Yes” indicates that the topic was included in the discussion guide for the discussion type indicated in column header. “No” indicates that this topic was not included in the discussion guide. Two group discussions were held that included representatives from five states.

a Indicates the number of states or organizations that participated.

For this project, we reached out to a small group of state APCD leaders willing to participate. States recruited for this project had long-standing APCDs, contributed to a geographically diverse sample, and were deemed likely to participate given their engagement with previous ASPE-supported studies on APCDs or participation in other multi-state initiatives. This outreach began with a set of one-hour semistructured discussions with leaders from six state APCDs: Colorado, Maryland, Massachusetts, Oregon, Utah, and Virginia. These discussions were conducted separately with individual state representatives.

We then facilitated two one-hour group discussions on the topic of linking APCD data to additional data sources, such as vital records, hospital discharge data, and cancer registries. Each group discussion included representatives from two or three of the states that participated in the initial discussions, for a total of five states. State participants included state APCD leaders and/or state experts in linking APCD data.

In addition, we conducted one-hour semistructured discussions with two additional stakeholder groups: (1) data vendors that provide services to state APCDs and (2) independent researchers from academic and nonprofit organizations who have conducted research using multiple state APCDs. Data vendors were identified via suggestions from state APCDs and a recent report (McAvey, 2022). Researchers, all from universities and nonprofit, nongovernmental organizations, were identified based on suggestions from state APCDs and a review of the annotated bibliography of a recent literature review focused on studies using data from more than one APCD (Carman et al., 2022). Invitations were extended to four data vendors and five researchers; discussions were completed with three data vendors and four researchers. The discussion guides used in this project are included in Appendix A in this report.

All discussions were conducted virtually as one-hour video meetings on Microsoft Teams. Participants were not paid. Discussions were led by a member of the project team, with a second team member taking contemporaneous notes. After finalizing the notes, we reviewed these notes and summarized key themes that emerged across the discussions.

This project was determined to be exempt from further human subjects review by the RAND Human Subjects Protection Committee.

### Example Multi-State Use Cases and Prototype Common Data Application

Concurrently with the stakeholder outreach described above, we produced three documents requested by ASPE, which are included as appendixes in this report.

#### Example Use Cases: Insulin Out-of-Pocket Costs and Long COVID

To help illustrate the value of multi-state APCD use cases, two preliminary research use cases were developed: one for a multi-state analysis of OOP costs paid by insulin users and another for a multi-state analysis of health care costs attributable to long coronavirus disease (COVID). Without confining the analysis to any specific set of states, we identified a set of research questions of potential interest to policymakers and that could be addressed through a one-year study using APCD data. We then developed a research plan for addressing the questions identified in each use case, including a definition of the study population, high-level definitions of key measures in terms of data elements captured in APCDs, a plan for the analysis (including illustrative table shells), and a discussion of study limitations and other interpretive considerations. Finally, noting that neither example use case fully specifies all the procedures and choices that would be needed to implement these analyses, we discuss additional steps that would be necessary to execute each use case. In the insulin use case, for example, we identify resources to identify insulin prescriptions using National Drug Codes (NDCs), but we do not include the code lists necessary to implement the study.

Both use cases offer guidance on two possible approaches to a multi-state study. First, we describe a possible study approach that could be implemented in a single state alone as an initial step toward a multi-state analysis. For these analyses, a multi-state research plan would promote comparability of findings across states by supporting standardization of data processing, selection of the population of interest, measure definition, and analytic methods—steps that are necessary but not sufficient to allow meaningful cross-state comparisons. Second, we discuss research questions of potential interest (such as comparisons of state-average outcome measures) that could only be addressed using multi-state data. Our intent in describing these multi-state use cases is to illustrate the potential value of multi-state APCD use cases while also surfacing challenges to the execution and interpretability of such studies.

Example use cases were circulated to state partners for written feedback. Revisions motivated by the states’ feedback were incorporated into the example use cases included in the appendix, and we discuss state perspectives on the value of these example use cases and other possible multi-state applications of APCD data in Chapter 2.

#### Prototype Common Data Application

A prototype common application was constructed that could potentially be used by researchers or other data users to request data from multiple states. We developed this prototype by reviewing elements that appear in the existing APCD data applications from the six states that participated in the project, the Agency for Healthcare Research and Quality’s Healthcare Cost and Utilization Project (HCUP) purchase request, the Centers for Medicare & Medicaid Services (CMS) Research Data Assistance Center’s (ResDAC’s) data application, and conversations with key stakeholders. The resulting application includes data items common to the participating states and captures common themes observed across data applications.

The exercise of developing a prototype common data application yielded insights about areas of convergence and divergence across states with respect to the information requested in their application forms. These findings are presented as inline annotations in the prototype common data application included in the appendix of this report. While discussing barriers to and potential facilitators of multi-state APCD applications, we asked states for their perspectives on the value of a common data application.

## Organization of This Report

The body of this report is organized thematically into two chapters that synthesize findings from the discussions. In Chapter 2, we present findings on the suitability of currently existing APCDs for patient-centered outcomes research and discuss options for improving on existing APCD data, including challenges and strategies related to missing data and missing populations. In Chapter 3, we present findings on multi-state uses of APCDs and discuss state and other stakeholder perspectives about current uses of multi-state APCD data, the potential value of multi-state APCD data, barriers to using multi-state APCD data, and strategies for facilitating multi-state APCD use cases. In Chapter 4, we conclude with a recap of high-level findings regarding expanded use of APCDs for patient-centered outcomes research and multi-state analyses, focusing on issues and possible actions identified by stakeholders.

1 In this report, we use the acronym PCOR only when “patient-centered outcomes research” is used as a modifier, as in “PCOR studies.”